# Conclusions

We identified specific research needs that may be useful in future efforts to address the efficacy and comparative effectiveness of PT treatments for patients with knee OA. Future research on these topics will create a broader and stronger evidence base for making clinical decisions:

- Which patient-centered outcome measurement instruments should be used consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)?
- Which intermediate outcome measurement instruments should be used consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)?
- Should effectiveness research on PT treatments use MCIDs?
- What confounding and effect modifying variables (e.g. OA severity, obesity, comorbidities, and concomitant therapies, including anti-inflammatory and analgesic medication) should be measured and reported in effectiveness research?
- What minimum set of treatment factors (site, treatment components, frequency, duration, intensity, timing) should be reported consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)?
- Which PT treatments work for which patients?
- How do the duration, intensity, and frequency of examined interventions affect sustained changes in patient-centered outcomes?
- What is the comparative effectiveness of comprehensive multimodal PT treatments on patient-centered outcomes when compared with exercise alone?
- In individuals who proceed to joint replacement surgery, do patients who underwent PT treatments prior to surgery fare better postoperatively?