# Background

## Context

This Future Research Needs (FRN) project is a followup to the draft Comparative Effectiveness Review (CER) “Physical Therapy Interventions for Knee Pain Secondary to Osteoarthritis.” The review was motivated by uncertainty around the effectiveness and comparative effectiveness of physical therapy (PT) treatments for adult patients with knee pain secondary to osteoarthritis (OA). FRN projects identify gaps in the current research that limit the conclusions in CERs and inform those who conduct and fund research of these gaps. FRN projects aim to encourage research likely to fill gaps and make the body of evidence more useful to decisionmakers. The report addressed the following Key Questions (KQs):

KQ 1 What are the effectiveness and comparative effectiveness of available PT interventions (without drug treatment) for adult patients with chronic knee pain due to OA on intermediate and patient-centered outcomes when compared with no active treatment or another active PT modality?
  a. Which patient characteristics are associated with the benefits of examined interventions of PT on intermediate and patient-centered outcomes?
  b. Do changes in intermediate and patient-centered outcomes differ by the dose, duration, intensity, and frequency of examined interventions of PT?
  c. Do changes in intermediate and patient-centered outcomes differ by the time of followup?
KQ 2 What is the association between changes in intermediate outcomes with changes in patient-centered outcomes after PT interventions?
  a. What is the validity of the tests and measures used to determine intermediate outcomes of PT on OA in association with patient-centered outcomes?
  b. Which intermediate outcomes meet the criteria of surrogates for patient-centered outcomes?
  c. What are minimal clinically important differences (MCIDs) of the tests and measures used to determine intermediate outcomes?
KQ 3 What are the harms from PT interventions available for adult patients with chronic knee pain due to OA when compared with no active treatment or active controls?
  a. Which patient characteristics are associated with the harms of examined PT interventions?
  b. Do harms differ by the duration of the treatment and time of followup?

### Physical Therapy for Knee Osteoarthritis

OA, the most common form of arthritis,1 is a progressive disorder characterized by gradual loss of cartilage and the development of bony spurs and cysts at the surface and margins of the joints. Inflammation, pain, stiffness, limited movement, and possible deformity of the joint may result.2 In the United States OA of the knee afflicts 28 percent of adults over age 45^3^ and 37 percent of adults over age 65.^3–6^ OA is a leading cause of disability among noninstitutionalized adults;4 those affected by it have slower gait velocities and use more assistive walking devices and nonsteroidal anti-inflammatory drugs and narcotics than those not affected. Further, the Centers for Disease Control and Prevention anticipates that the prevalence, health impact, and economic consequences of OA will surge during the next few decades as the population ages.7

Treatments for OA aim to reduce or control pain, improve physical function, prevent disability, and enhance quality of life—all of which constitute clinical outcomes of importance to patients.8,9 Treatment options include pain relievers, anti-inflammatory drugs, weight loss, general physical exercise, PT, and, when conservative treatments fail, surgery.9

Comprehensive, up-to-date guidelines are available from the Osteoarthritis Research Society International, the American Academy of Orthopedic surgeons, and the National Institute for Health and Clinical Excellence. These guidelines recommend exercise (including local muscle strengthening and general aerobic fitness) as a core treatment for symptomatic OA, irrespective of patient age, comorbidity, pain severity, or disability.9–11 Effectiveness has not been clearly established for other nonpharmacologic PT interventions as adjunct to core treatment (e.g. thermal, manipulation, electrical nerve stimulation, and orthotics).9

The analytic framework adapted from the original draft CER (Figure 1) simplifies the process experienced by adults with knee pain secondary to OA once they are referred for PT. The actual practice of PT, condensed to a single point in the analytical framework, is a complex process. Traditionally, a patient is seen by a primary care provider or specialist for knee pain. This provider may then diagnose OA and refer the patient for PT. Encounters with the physical therapist are comprehensive. The Guide to Physical Therapy Practice describes five elements of patient management leading to optimal outcomes.12

- [underlined: Examinatio]n—Patient history, screening, and specific testing to inform treatment.
- [underlined: Evaluation]—Physical therapist makes clinical judgments based on information gathered during examination.
- [underlined: Diagnosis]—Process and end result of evaluation, organized into categories to help determine prognosis and plan of care.
- [underlined: Prognosis] (including plan of care)–Determination of level of optimal improvement and interventions, duration, timing, and frequency.
- [underlined: Intervention]–Purposeful and skilled interaction of the physical therapist with the patient to produce changes consistent with diagnosis and prognosis. Reexamination to determine changes in patient status and to modify/redirect intervention based upon clinical findings or lack of progress.

Figure 1 Analytic framework

KQ = Key Question; OA = osteoarthritis; PT = physical therapy

Figure 1 depicts the key questions within the context of the PICOTS. In general, the figure illustrates how different physical therapy interventions in adults with knee osteoarthritis may improve intermediate outcomes (e.g., joint movement, swelling, inflammation, or impairments in performance tests) and patient-centered outcomes (e.g., pain, activities of daily living, decreased disability; return to work/activities, or quality of life). Adverse events may occur at any point after treatment is received. Treatment effects may be modified by age, gender, race, baseline ADL/IADL disability, comorbidity, concomitant/prior treatments, activity level, or occupation. The figure also illustrates the questions about the validity, reliability, and minimal clinically important difference of the tests and measures to determine intermediate outcomes (e.g. manual muscle test, hand held dynamometer, isokinetic dynamometer). Dotted line points out the association between changes in intermediate outcomes with the changes in patient-centered outcomes.

The draft CER specifically addressed individual PT interventions; however, in PT practice, the plan of care includes specific interventions or combinations of interventions that are carefully chosen according to patient characteristics and condition status (i.e., symptoms such as pain, functional limitations, inflammation, etc.) (Figure 2). How each intervention fits into the plan of care highlights the relevant outcome by which its effectiveness should be measured.

Figure 2 Physical therapy for knee osteoarthritis: intervention algorithm

Figure 2 describes an algoriythm that explains how treatments for knee OA might work in PT practice, as informed by The Guide to Physical Therapy Practice which describes five elements of patient management leading to optimal outcomes. •Examination—Patient history, screening, and specific testing to inform treatment. •Evaluation—Physical therapist makes clinical judgments based on information gathered during examination. •Diagnosis—Process and end result of evaluation, organized into categories to help determine prognosis and plan of care. •Prognosis (including plan of care)–Determination of level of optimal improvement and interventions, duration, timing, and frequency. •Intervention–Purposeful and skilled interaction of the physical therapist with the patient to produce changes consistent with diagnosis and prognosis. Reexamination to determine changes in patient status and to modify/redirect intervention based upon clinical findings or lack of progress.

Plans of care may include primary therapies aimed at decreasing pain and improving function as well as supplemental therapies aimed at removing barriers to or enhancing participation in primary therapies. For instance, exercise therapy is often considered a core therapy for patients with knee pain secondary to OA. However, not all patients can initially tolerate exercise therapy due to pain or limited function. In these cases, adjunct therapies such as manual therapy, taping, or transcutaneous electrical nerve stimulation may be incorporated into the plan of care in order to reduce pain and enable fuller participation in exercise therapy and other physical activity. The same therapies used as adjunct therapies may also be used as stand-alone therapies.

PT practice emphasizes the careful monitoring each patient’s condition status and progress with the plan of care throughout treatment so that the plan of care can be altered as needed to optimize participation and outcomes.

### Findings of the Draft Comparative Effectiveness Review

The authors of the draft review found that the evidence for KQ 1 supported the use of various forms of exercise therapy and ultrasound. Exercise therapy was efficacious when supervised by a physical therapist and typically resulted in a clinically meaningful improvement in pain and disability outcomes. The evidence comparing various forms of exercise therapy demonstrated similar benefits in disability measures for aerobic, aquatic, and strengthening exercise. Adherence to exercise therapy was the key to efficacy. Diathermy, orthotics, and magnetic stimulation used as stand-alone therapies demonstrated no benefit. Evidence was insufficient to conclude the best treatment option among PT interventions or to conclude differences in effects by patient characteristics. No consistent associations between the duration of examined interventions or followup times and intermediate/patient-centered outcomes were found.

For KQ 2, the intermediate outcomes of gait, mobility restrictions, muscle strength, and range-of-motion measures were associated with patient-centered disability measures in individual studies. However, these intermediate measures could not adequately predict patient-centered outcomes. MCIDs in scales were determined for 26 scales, but therapeutic studies did not consistently evaluate treatments using MCIDs. The Patient Acceptable Symptom State, a threshold for patient satisfaction, was available for three patient-centered outcomes scales.

For KQ 3, the authors found that adverse events were uncommon and not severe enough to deter participants from continuing treatment.

Study quality and heterogeneity in populations and treatments, including concomitant treatments, downgraded the strength of evidence to low or moderate in most cases. The authors also identified gaps in evidence limiting their ability to draw definitive conclusions. There were a limited number of comparative effectiveness studies, and efficacy studies primarily addressed stand-alone therapies rather than combinations, which are more common in current clinical practice. The CER did not address whether adjunct therapies were effective for enabling patients to more fully participate in core therapies as intended. Which patients are likely to benefit from exercise therapy alone and which ones may need a broader treatment approach was not clearly established. Evidence was insufficient to draw conclusions about the most effective activities (aerobic, strength, etc.) or dosage (intensity, frequency, duration) within exercise therapy. Evidence about long-term effectiveness of PT interventions is limited. One systematic review suggests that long-term effectiveness is enhanced by followup booster sessions.13

### Objective

This FRN project identifies and prioritizes specific gaps in the current literature on PT for knee pain due to OA that would, if addressed, aid decisionmakers. We used a deliberative process to identify specific research needs along with research design considerations meant to advance the field.

## Evidence Gaps and Research Question Development

As with much of the research on functional therapies, many studies of PT interventions for patients with knee pain secondary to OA exhibited problems with design and conduct. Our original report included recommendations to improve future research on this topic. We refined and developed the list of evidence gaps listed in the draft report and phrased the gaps as research questions. This preliminary set of research questions (below) are separated into two categories: (1) methodological research questions that need to be addressed to enhance the usefulness of current research and (2) topical research questions that have not been sufficiently addressed within the current literature.

### Methodological Research Questions

1. How should combined PT interventions be defined to facilitate hypothesis testing and provide sufficient evidence applicable to current PT practice?
2. How do patient-centered outcomes differ depending on the involvement of a physical therapist or physical therapist assistant, group versus individual exercise, and self-administered versus supervised exercises?
3. What are the valid and reliable instruments used to measure patient-centered outcomes?
  - Pain/Independence in actives of daily life/instrumental activities of daily life
  - Patient satisfaction
  - Time to return to work/activities
  - Quality of life
  - Community integration
  - Psychological disability
  - Self-perceived health
  a. What is the minimum clinically important difference (MCID) for each of these valid and reliable instruments?
  b. What cutpoints should be used to describe clinically meaningful categories in the scale scores created by these instruments?
4. What are the valid and reliable instruments used to measure the following intermediate outcomes when evaluating the effectiveness and comparative effectiveness of PT interventions for knee pain secondary to OA?
  - Joint function
  - Swelling
  - Inflammation
  - Gait function
  - Strength
  - Transfers
5. Which intermediate outcomes meet the criteria for surrogate patient-centered outcomes?
6. What confounding variables (e.g., compliance, weight loss, activity levels), and effect modifiers including concomitant therapies should be controlled for?

### Topical Research Questions

1. What is comparative effectiveness of combined PT interventions for adult patients with chronic knee OA on patient-centered outcomes?
2. What is the marginal benefit from individual treatment modalities (e.g. heat, ice) delivered in the appropriate stage or status of OA?
3. Which patient characteristics are associated with patient-centered outcomes resulting from examined combined or single PT interventions?
  - Age
  - OA severity
  - Multi-joint OA
  - Concomitant treatment
  - Comorbidity
4. Do sustained changes in patient-centered outcomes differ by the duration, intensity, and frequency of examined interventions?
5. What are the harms of PT interventions for knee pain secondary to knee OA?