# Recent and Ongoing Studies

## Recently Published Studies

1 Deyle GD, Gill NW, Allison SC, et al. Knee OA: which patients are unlikely to benefit from manual PT and exercise?. Journal of Family Practice. Jan. 2012;61(1):E1-8. [pmid: 22220299].
2 Gundog M, Atamaz F, Kanyilmaz S, et al. Interferential current therapy in patients with knee osteoarthritis: comparison of the effectiveness of different amplitude-modulated frequencies. American Journal of Physical Medicine & Rehabilitation. Feb. 2012;91(2):107-13. [pmid: 22019968].
3 Hale LA, Waters D, Herbison P. A randomized controlled trial to investigate the effects of water-based exercise to improve falls risk and physical function in older adults with lower-extremity osteoarthritis. Archives of Physical Medicine & Rehabilitation. Jan. 2012;93(1):27-34. [pmid: 21982325].
4 Hurley MV, Walsh NE, Mitchell H, et al. Long-term outcomes and costs of an integrated rehabilitation program for chronic knee pain: a pragmatic, cluster randomized, controlled trial. Arthritis Care & Research. Feb. 2012;64(2):238-47. [pmid: 21954131].
5 Loyola-Sanchez A, Richardson J, Beattie KA, et al. Effect of low-intensity pulsed ultrasound on the cartilage repair in people with mild to moderate knee osteoarthritis: a double-blinded, randomized, placebo-controlled pilot study. Archives of Physical Medicine & Rehabilitation. Jan. 2012;93(1):35-42. [pmid: 22200383].
6 Sayers SP, Gibson K, Cook CR. Effect of high-speed power training on muscle performance, function, and pain in older adults with knee osteoarthritis: a pilot investigation. Arthritis Care & Research. Jan. 2012;64(1):46-53. [pmid: 22012877].
7 Kettunen JA, Harilainen A, Sandelin J, et al. Knee arthroscopy and exercise versus exercise only for chronic patellofemoral pain syndrome: 5-year follow-up. British Journal of Sports Medicine. Mar. 2012;46(4):243-6. [pmid: 21357578].

## Ongoing Studies

NCT Number | Title | Interventions
NCT00000404 | Effects of Comprehensive Care for Knee OA | Behavioral: Patient education in self-care of knee OA
NCT00000406 | Effects of Strength Training on Knee Osteoarthritis | Procedure: Progressive resistance exercise
NCT00007241 | Muscle Strengthening Device for Knee Osteoarthritis | Device: Isometric exercise
NCT00049816 | Aerobic Exercise Intervention for Knee Osteoarthritis | Behavioral: Walking exercise\|Behavioral: Cycling Exercise
NCT00061490 | The Effect of Weight Loss and Exercise on Knee Osteoarthritis | Behavioral: Behavioral weight control and lifestyle exercise
NCT00078624 | Knee Stability Training for Knee Osteoarthritis (OA) | Other: Traditional exercise therapy for knee osteoarthritis\|Other: Knee stability training
NCT00085722 | Joint Injections for Osteoarthritic Knee Pain | Procedure: Dextrose Prolotherapy\|Procedure: Saline Prolotherapy\|Other: At-home physical therapy exercise group
NCT00104156 | Qigong Therapy for Individuals With Knee Osteoarthritis | Procedure: External Qigong therapy
NCT00123994 | Tai Chi or Hydrotherapy for People With Osteoarthritis of the Hip(s) or Knee(s) | Behavioral: Tai Chi classes\|Behavioral: Hydrotherapy classes
NCT00154765 | Effect of Sling Suspension Exercises in Proprioception of Patients With Knee Osteoarthritis | Device: sling suspension exercises
NCT00265447 | Exercise and Physical Fitness for Persons With Knee Osteoarthritis | Behavioral: self-directed exercise\|Behavioral: 3 months of aerobic conditioning
NCT00305890 | Weight Management and Coping Skills Training For Patients With Knee Osteoarthritis | Behavioral: Lifestyle Behavioral Weight Management Program\|Behavioral: Pain-Coping Skills Training\|Other: Standard Care
NCT00362453 | Tai Chi Mind-Body Therapy for Knee Osteoarthritis | Behavioral: Tai Chi versus Attention Control
NCT00375544 | Study to Evaluate the Safety and Efficacy of a Low Level Light Device in Patients With Knee Osteoarthritis | Device: Low level light therapy
NCT00381290 | Intensive Diet and Exercise for Improving Knee Osteoarthritis in Obese and Overweight Older Adults | Behavioral: Diet\|Behavioral: Exercise
NCT00415259 | Effects of Shoes Insoles on Symptoms and Disease Progression in Knee Osteoarthritis | Device: Laterally wedged shoe insoles
NCT00427843 | The Influence of Hip Strengthening Exercises on Walking Patterns and Muscle Strength in Persons With Knee Osteoarthritis | Behavioral: home exercise program for the hip abductor muscles
NCT00462319 | ARTIST: ARThrose Intervention STandardisée | Behavioral: Education, weight reduction and physical exercise
NCT00465660 | Resistive Exercise for Arthritic Cartilage Health (REACH) | Behavioral: Progressive resistance training
NCT00492674 | The Effect of Perioperative Neuromuscular Training on the Outcome of Total Knee Arthroplasty | Device: APOS biomechanical gait system\|Procedure: Physical Therapy
NCT00493142 | Pre-operative Rehabilitation Exercise Program for Total Knee Arthroplasty | Behavioral: Exercise
NCT00519922 | A Study of the Effectiveness of Different Types of Exercise for People With Knee Osteoarthritis | Other: Kinesthesia, Balance, and Agility (KBA) Exercise\|Other: Standard LE Strength Training
NCT00522106 | The Effectiveness of Behavioral Graded Activity in Patients With Osteoarthritis of the Hip and/or Knee | Behavioral: Behavioral graded activity\|Other: Exercise therapy
NCT00583245 | Improving Walking in Older Adults With Knee Osteoarthritis | Other: Gait Training
NCT00586300 | Community-Based Programs for Improving Physical Function in People With Early Knee Osteoarthritis | Other: Physical training program\|Behavioral: Self-management training program\|Other: Physical training and self-management training programs
NCT00642772 | Group Physical Therapy for Knee Osteoarthritis | Other: Group Physical Therapy
NCT00655941 | Influence of Weight Loss or Exercise on Cartilage in Obese Knee Osteoarthritis Patients | Behavioral: Dietary instruction\|Other: Exercise
NCT00687726 | Simple Home-Based Exercise for Knee Osteoarthritis | Behavioral: Standing balance exercise\|Behavioral: Isometric knee extension exercise
NCT00701506 | Patterned Electrical Neuromuscular Stimulation and Therapeutic Exercise for Osteoarthritis of the Knee: Pilot Study | Device: Patterned Electrical Neuromuscular Stimulation\|Device: Placebo PENS
NCT00726492 | An Examination of the Value of Shortwave Diathermy and Hydrotherapy for Patients With Osteoarthritis of Their Knees | Other: Continuous short wave diathermy (CSWD)\|Other: Hydrotherapy
NCT00735098 | The Effects of Home-Based Rehabilitation Treatments Among Persons With Symptomatic Knee Osteoarthritis | Other: KBA exercise\|Other: strength training exercise\|Other: KBA and strength training\|Other: Control group
NCT00800254 | Early Neuromuscular Electrical Stimulation For Quadriceps Muscle Activation Deficits Following Total Knee Replacement | Procedure: Neuromuscular Electrical Stimulation (NMES)\|Behavioral: Standard Rehabilitation Protocol
NCT00844558 | Mobility Optimization Through Velocity Exercise | Other: Gait Training\|Other: Power Training\|Other: Control
NCT00904319 | Aquatic Power Training | Other: Aquatic Power Training
NCT00913575 | Effect of Pre-surgery Neuromuscular Physiotherapy (PT) | Other: preoperative neuromuscular training\|Behavioral: knee OA School
NCT00917618 | The Effects of Group Cycling (Spinning®) With Knee Osteoarthritis: A Randomized Control Trial | Other: Exercise\|Other: Control
NCT00950326 | A Comparison of Kneipp Hydrotherapy With Conventional Physiotherapy in the Treatment of Osteoarthritis of the Hip or Knee: Protocol of a Prospective Randomised Controlled Clinical Trial | Procedure: Physiotherapy\|Procedure: Affusion\|Procedure: Affusion/ Physiotherapy
NCT00976079 | The Effect of Transcutaneous Electrical Nerve Stimulation on Quadriceps Central Activation and Gait | Device: Transcutaneous electrical nerve stimulation (TENS)\|Device: Placebo TENS
NCT00979043 | The Arthritis, Diet, and Activity Promotion Trial | Behavioral: Dietary Weight-loss\|Behavioral: Exercise
NCT00979914 | Effect of an Education Programme for Patients With Osteoarthritis in Primary Care - a Randomized Controlled Trial | Other: Patient education programme
NCT00988468 | Manual Therapy Versus Exercise on Knee Osteoarthritis | Procedure: Manual Therapy\|Behavioral: Therapeutic Exercise\|Behavioral: Video Observation
NCT01003756 | Preoperative Exercise in Patients Undergoing Total Hip or Knee Replacement | Other: Preoperative neuromuscular exercise
NCT01003925 | Conjoint Analysis of Treatment Preferences for Osteoarthritis | Behavioral: Standard of care for osteoarthritis treatment\|Behavioral: Conjoint Analysis for Osteoarthritis
NCT01017445 | Stick Versus Quadricep Exercise for Knee Osteoarthritis | Other: Boonme stick exercise
NCT01058304 | Group Physical Therapy for Knee Osteoarthritis | Other: Group Physical Therapy for Knee OA\|Other: Individual Physical Therapy for Knee OA
NCT01096524 | Effects of Kneehab 12-week Peri-operative Total Knee Arthroplasty | Other: Standard Physiotherapy\|Device: Kneehab
NCT01099371 | Resistance Training in Knee Osteoarthritis | Other: exercise
NCT01112319 | The Effects of the Electro, Heat and Cold -Therapy During Physiotherapy Treatment in Osteoarthritis(OA) of KNEE | Device: Elf care\|Other: control group
NCT01210742 | The Efficacy of Viscosupplementation for Early Knee Osteoarthritis | Device: Synvisc One
NCT01225133 | Complex Āyurvedic Treatment in Osteoarthritis of the Knee Compared to Standard Care. | Other: Complex Ayurvedic Treatment\|Other: Conventional Care
NCT01239823 | Platform Exercise Training | Other: Whole Body Vibration Training\|Other: Exercise without vibration
NCT01241812 | Biomarkers and Knee Osteoarthritis | Behavioral: Lower limb muscle strengthening\|Behavioral: Usual care
NCT01245283 | Resistance Exercise and Knee Osteoarthritis Pain, Functional Impairment and Cartilage Turnover | Other: normal activities and clinical care\|Other: Concentric Focused Resistance Exercise\|Other: Eccentric Focused Resistance Exercise
NCT01258985 | Tai Chi and Physical Therapy for Knee Osteoarthritis | Behavioral: Tai Chi\|Behavioral: Physical Therapy
NCT01271218 | Effects of Glucosamine and Chondroitin Supplementation in Women With Knee Osteoarthritis Participating in an Exercise and Weight Loss Program | Other: Diet\|Other: Exercise
NCT01280903 | Staying Active With Arthritis | Behavioral: STAR Intervention\|Behavioral: Attention-Control
NCT01306435 | Low Power Laser and Exercise in Osteoarthritis of the Knee: a Randomized Clinical Trial | Other: Laser\|Other: Placebo Laser
NCT01311206 | Low Intensity Resistance Training With Partial Blood Flow Restriction for Quadriceps Strengthening | Other: partial blood flow restriction\|Other: Low intensity exercise without partial blood flow restriction
NCT01314183 | Enhancing the Effectiveness of Physical Therapy for People With Knee Osteoarthritis | Other: Exercise\|Other: manual therapy
NCT01328340 | High-speed Power Training in Older Adults With Knee Osteoarthritis (OA) | Other: weight training
NCT01331174 | Pulsed Short Wave in Females With Knee Osteoarthritis | Device: Pulsed short wave
NCT01345825 | The Effectiveness of 8-weeks Progressive Strength Training to Patients With Unicompartmental Knee Replacement, Initiated Within the First Postoperative Week | Other: Resistance training
NCT01354860 | Moxibustion for Knee Osteoarthritis | Other: Moxibustion treatment plus usual care\|Other: Usual care alone group
NCT01360281 | Neuromuscular Electrical Stimulation and Strength Training in Patients With Knee Osteoarthritis | Other: Neuromuscular Electrical Stimulation\|Other: ECR
NCT01394874 | Can Computer-based Telephone Counseling Improve Long-term Adherence to Strength Training in Elders With Knee OA? | Behavioral: TLC
NCT01410240 | Efficacy and Safety of FLOSEAL for Hemostasis in Total Knee Arthroplasty | Other: Standard of Care\|Drug: FLOSEAL Hemostatic Matrix
NCT01410409 | Structured Treatment of Osteoarthritis of the Knee With or Without Total Knee Replacement | Other: Neuromuscular training (NEMEX-TJR)\|Drug: Paracetamol\|Drug: Burana\|Drug: Pantoprazol\|Behavioral: Dietary counseling\|Behavioral: Patient education\|Procedure: TKR\|Other: Insoles
NCT01427153 | A Comparison of Manual Physical Therapy and Corticosteroid Injections for Knee Osteoarthritis | Procedure: Orthopaedic manual physical therapy\|Procedure: Corticosteroid Injection
NCT01440972 | Assessment of Efficacy of Low Intensity Resistance Training in Women at Risk for Symptomatic Knee Osteoarthritis | Other: partial blood flow restriction (PBFR)\|Other: low intensity resistance training
NCT01483131 | Vascular Occlusion in Patients With Osteoarthritis | Other: Exercise training\|Other: Resistance training with vascular occlusion
NCT01487525 | Assessment of Efficacy of Low Intensity Resistance Training in Individuals at Risk for Symptomatic Knee Osteoarthritis | Device: double leg press with partial blood flow restriction\|Other: double leg press without partial blood flow restriction
NCT01489462 | Strength Training for ARthritis Trial | Behavioral: High Intensity Strength Training\|Behavioral: Low Intensity Strength Training\|Behavioral: Attention Control
NCT01490606 | Knee Osteoarthritis (OA) Project Treatment Versus Conventional Physical Therapy in the Treatment of Knee OA Patients | Other: knee OA project\|Other: conventional PT
NCT01528566 | Effect of Tai Chi on Osteoarthritic Knee Pain in Elders With Mild Dementia | Behavioral: Tai Chi\|Behavioral: Attention control
NCT01529398 | Sensorimotor Training Versus Resistance Training in Patients With Knee Osteoarthritis | Other: Sensorimotor training (SMT)\|Other: Resistance training (RT)\|Other: Control group (CG)
NCT01530204 | RAPID: Reducing Pain; Preventing Depression | Procedure: Physical Therapy for knee OA\|Behavioral: Cognitive Behavioral Therapy for Pain CBT-P\|Other: Enhanced Treatment as Usual
NCT01535001 | Structured Non-operative Treatment of Knee Osteoarthritis | Other: Neuromuscular training (NEMEX-TJR)\|Behavioral: Information\|Drug: Paracetamol\|Drug: Burana\|Drug: Pantoprazole\|Behavioral: Dietary counseling\|Behavioral: Patient education\|Other: Insoles
NCT01538407 | Strengthening Exercise and Quadriceps Force During Walking | Other: Strength Training
NCT01544647 | Spa Therapy in Knee Osteoarthritis (OA): Nancy-thermal | Other: Usual spa protocol\|Other: Active spa protocol
NCT01545258 | Exercise and Pain Sensitivity in Knee Osteoarthritis | Other: Exercise
NCT01545986 | A Comparative Analysis of Two Types of Exercise on Outcomes Following Total Knee Arthroplasty | Behavioral: Exercise
NCT01576159 | Serum Cartilage Oligomeric Matrix Protein Accumulation Decreases Significantly After 12 Weeks of Running | Other: Running exercise\|Other: Cycling exercise\|Other: Swimming Exercise
NCT01586130 | Assessing the Impact of Isokinetic Muscular Strengthening in Eccentric Mode in the Medical Treatment of Knee Osteoarthritis | Other: Exercise in eccentric or concentric mode