# Search Strategy for Recently Published Studies

## Ovid Medline Search Strategy

1. exp *Physical Therapy Modalities/ (78040)
2. physical therap*.ti,ab. (10871)
3. 1 or 2 (84208)
4. exp *Osteoarthritis, Knee/ (6654)
5. osteoarthritis.ti,ab. (28073)
6. knee.ti,ab. (72016)
7. 4 or 5 or 6 (90745)
8. 3 and 7 (3120)
9. limit 8 to yr=”2012” (38)

## Advanced search for Intervention studies on ClinicalTrials.gov

physical therapy or exercise in the intervention field

and (osteoarthritis and knee) in the condition field