# Research Gap Questions for Prioritization

## Methods Issues Needing Consensus

1. How should Knee OA severity be graded consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)?
2. How should multimodal PT treatments be classified?
3. Should effectiveness research on PT treatments use minimal clinically important differences (MCID)?
4. Which patient-centered outcome measurement instruments should be used consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)?
5. Which intermediate outcome measurement instruments should be used consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)?
6. What confounding and effect modifying variables (e.g., OA severity, obesity, comorbidities, and concomitant therapies—including anti-inflammatory and analgesic medication) should be measured and reported in effectiveness research?
7. What minimum set of treatment factors (site, treatment components, frequency, duration, intensity, timing) should be reported consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)?

## PT for Knee OA Topical Questions

1. Which PT treatments work for which patients?
2. Do periodic followup treatments beyond the initial PT treatments enhance effectiveness?
3. What is the long-term effectiveness of PT treatments on patient centered outcomes?
4. What is the comparative effectiveness of comprehensive multimodal PT treatments on patient-centered outcomes when compared with exercise alone?
5. What is the comparative effectiveness over the entire course of different comprehensive multimodal PT programs (from initial PT-directed treatments through self-management and occasional followup treatments)?
6. Does PT for knee OA delay time to surgery?
7. Does PT for knee OA reduce medication use?
8. Do PT treatments affect structural joint changes?
9. In individuals who proceed to joint replacement surgery, do patients who underwent PT treatments prior to surgery fare better postoperatively?
10. How does the method of delivery (e.g., the involvement of a physical therapist or physical therapist assistant, group versus individual exercise, self-administered versus supervised exercises, etc.) affect patient-centered outcomes?
11. How do the duration, intensity, and frequency of examined interventions affect sustained changes in patient-centered outcomes?