# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
EPC: Evidence-based Practice Center
FRN: Future Research Needs
KQ: Key Question
MCID: Minimum Clinically Important Difference
NIA: National Institute on Aging
OA: Osteoarthritis
PICOTS: Population, intervention, comparison, outcome, timing, and setting
PT: Physical therapy
RCT: Randomized controlled trials