# Results

## Research Needs

### Prioritization Results

Stakeholders separately ranked methodological and topical research questions. Of the 10 stakeholders invited to participate in the ranking process, 5 ranked methodological research questions and 4 ranked topical research questions. We analyzed weighted stakeholder rankings for each research question to identify natural breakpoints (Table 1). High-priority research questions were deemed research needs.

Table 1 Stakeholder prioritization of research gap questions

Question Ranking^*^ | Total (Points) | PICOTS Element
Methodological Topics Needing Consensus (n=5)
Tier 1: High Priority
Which [underlined: patient characteristics] confound/modify effectiveness of rehabilitation programs? | 8 | P
What outcomes of multidisciplinary rehabilitation are most important to:; - Patients; - Families; - Payers | 7 | O
Tier 2: Moderate Priority
How should patient readiness for multidisciplinary rehabilitation programs be measured? | 5.8 | P, I
Which injury characteristics confound/modify effectiveness of rehabilitation programs? | 4.8 | P
What typology should be used to classify multidisciplinary rehabilitation programs? | 3 | I
Tier 2: Low Priority
Which intermediate outcomes adequately predict patient-centered outcomes (surrogate outcomes)? | 1 | O
What are the MCIDs for outcomes instruments?; a. What are the advantages and disadvantages to using MCIDs in research on this topic?; Should they be used to measure program effectiveness? | 0.3 | O
Topical Questions Needing Trials (n=4)
Tier 1: High Priority
Timing: At what stage of recovery do multidisciplinary rehabilitation programs offer the best chance of improvement to patients? | 7.5 | T
Which multidisciplinary rehabilitation programs are “promising practices?”; a. What benefits are experienced by patients participating in various multidisciplinary rehabilitation programs?; b. What outcomes appear to be most improved by various multidisciplinary rehabilitation programs?; c. Which patients (subgroups) appear to benefit most by various multidisciplinary rehabilitation programs?; d. What kinds of harms are experienced by patients participating in various multidisciplinary rehabilitation programs? | 5.5 | I
Sustainability and Followup: Are benefits received from multidisciplinary rehabilitation programs sustained over the long-term?; - What level and type of followup care allows for maintenance or prevents deterioration of rehabilitation gains at given time periods post rehabilitation? | 5 | O, T
Tier 2: Moderate Priority
Intervention Characteristics: Which intervention characteristics predict response in various forms of multidisciplinary rehabilitation programs? | 3.3 | I
Multidisciplinary rehabilitation program versus accessible rehabilitation: What is the comparative effectiveness of various types of multidisciplinary rehabilitation programs vs. rehabilitation typically covered by third party payers? | 2.3
Tier 3: Low Priority
Subgroups: Does the efficacy of specific multidisciplinary rehabilitation programs vary across patient subgroups? | 0.3 | P

Abbreviations: MCIDS = minimum clinically important differences; PICOTS = population, intervention, comparison, outcome, timing, and setting

* Rankings were weighted to create a total point score by assigning questions ranked #1 by stakeholders with 3 points, questions ranked #2 with 2 points, questions ranked #3 by stakeholders with 1 point. A forced ranking was used with responses that recording duplicate ratings.

### Ongoing Studies

We conducted a search for ongoing studies in ClinicalTrials.gov (search strategy appears in Appendix B). Our search identified 289 studies. Thirteen of these studies (Appendix C) were not yet published and relevant to the scope of our CER. These studies will provide valuable information, but we did not believe any ongoing study would sufficiently address identified future research questions.

## Methodological Research Needs

A natural breakpoint in weighted rankings revealed two methodological research needs. Addressing methodological research needs will enhance the utility and translation of current and future research on multidisciplinary rehabilitation programs for sustained impairments from moderate to severe TBI in adults:

- What outcomes of multidisciplinary rehabilitation are most important to:
  ○ Patients
  ○ Families
  ○ Payers
- Which [underlined: patient characteristics] confound/modify effectiveness of rehabilitation programs?

Methodological research needs pertain to identifying outcomes that are important to patients, families, and payers, and to identifying patient characteristics that influence response to rehabilitation.

### Considerations for Potential Research Designs

There are several ways that these methodological research needs could be addressed. Systematic reviews, epidemiological studies, and/or qualitative research would all assist in improving the understanding with regard to valued outcomes and factors than confound or modify the effect of TBI rehabilitation. One way to identify specific outcomes valued by patients may be to review the literature or secondary databases about TBI rehabilitation programs that use shared decisionmaking or goal setting among patients, families, and providers. Qualitative research would also be useful. Focus groups, for example, with representatives of patients, families, and payers—in separate focus groups—would help to identify these outcomes. Several patient and family focus groups would be necessary due to the wide range of impairment types and levels resulting from moderate to severe TBI. Preferred outcomes are likely associated with patient impairment types and levels at rehabilitation initiation.

Patient characteristics associated with the effectiveness of rehabilitation programs could be identified through similar methods. This process would benefit first from a systematic literature review. Several studies that examine patient characteristics and their influence on outcomes are available. A systematic review is not likely to provide the complete picture of confounding and effect modifying factors. Analysis of secondary databases and post hoc analysis of effectiveness studies establishing potential relationships between patient characteristics and patient outcomes should be included in such a systematic review. By definition, multidisciplinary rehabilitation programs involve several provider types; therefore, a multidisciplinary approach to consensus development is essential. Participants should include clinical experts and researchers with expertise in clinical outcomes, epidemiology, biostatistics, and health services research.

### Topical Research Needs

A natural breakpoint in the weighted rankings revealed three prominent topical research needs. These primarily addressed the PICOTS elements of interventions, outcomes, and timing; Addressing these issues will enhance understanding of efficacy and comparative effectiveness, which was limited in the draft CER.

#### First Topical Research Need

[underlined: Research Question:] Which multidisciplinary rehabilitation programs are “promising practices?”

a. What benefits are experienced by patients participating in various multidisciplinary rehabilitation programs?
b. What outcomes appear to be most improved by various multidisciplinary rehabilitation programs?
c. Which patients (subgroups) appear to benefit most by various multidisciplinary rehabilitation programs?
d. What kinds of harms are experienced by patients participating in various multidisciplinary rehabilitation programs?

The draft CER and peer review of that draft emphasized the limited value of rigorous Comparative Effectiveness Reviews on this topic given the complexity of rehabilitation programs for TBI impairments and the current status of this literature.

##### Research Design Considerations

The draft CER and peer review of that draft emphasized the limited value of rigorous Comparative Effectiveness Reviews on this topic given the complexity of rehabilitation programs for TBI impairments and the current status of this literature. As topics for Comparative Effectiveness Reviews have expanded beyond pharmaceutical interventions, alternative approaches have been proposed to synthesize research on complex interventions (characterized as programs in which effects are dependent on context and implementation). “Realist reviews” may be an option better suited to such topics.8 These reviews are rigorous systematic reviews, but focus more on explaining how, when, and why certain interventions may work or not work. This approach to a systematic review provides improved understanding of interventions and their populations and therefore may be a good fit for complex interventions such as rehabilitation.

Realist reviews seek to provide an explanatory analysis discerning what works for whom and under what circumstances. This information can help strengthen understanding of programs and inform efficient and effective implementation.8 Although realist reviews cannot achieve the goal of Comparative Effectiveness Reviews, which is, ideally, to identify what works and what does not, they can generate information that spurs hypotheses from which to design comparative effectiveness studies. A realist review could be useful in identifying promising practices. Research design considerations for a review of this type are described in Table 2.

Table 2 First topical research need research design considerations

Research Question: Which multidisciplinary rehabilitation programs are “promising practices?”; a. What benefits are experienced by patients participating in various multidisciplinary rehabilitation programs?; b. What outcomes appear to be most improved by various multidisciplinary rehabilitation programs?; c. Which patients (subgroups) appear to benefit most by various multidisciplinary rehabilitation programs?; d. What kinds of harms are experienced by patients participating in various multidisciplinary rehabilitation programs?
Considerations | Realist Review
Design Description | Systematic review of the literature that seeks to provide an explanatory analysis discerning what works for whom and under what circumstances.
Population | Studies evaluating rehabilitation effectiveness.
Intervention | Multidisciplinary rehabilitation program.
Comparator | Any control (may include uncontrolled studies).
Outcomes | Any outcomes measured in original studies.
Advantages for Producing a Valid Result | Results will be descriptive and explanatory and will not lead to definitive conclusions about efficacy or comparative effectiveness, but provide a more in-depth understanding of how, when, and why certain rehabilitation programs work and in which patients.
Resource use, size, and duration | Minimal, study can be conducted by secondary data analysis. Resource use includes investigator time and related resources. Investigator time will be significant.
Ethical, legal, and social issues | No ethical, legal, or social issues.
Availability of data/ability to recruit | Good, several studies are available. However, data will be limited to what is reported in original studies.

#### Second Topical Research Need

[underlined: Research Question:] At what stage of recovery do multidisciplinary rehabilitation programs offer patients the best chance of improvement?

Understanding the ideal timing to enroll those with impairments from moderate to severe TBI into rehabilitation programs is our second topical research need. This question was addressed by the CER KQs. However, data was too limited assess the influence of rehabilitation program timing. The CER did demonstrate the wide range of multidisciplinary rehabilitation programs studied. Some are aimed at those with recent injuries, others to those that have achieved medical stability, and others to those with chronic impairments. These programs likely vary widely with regard to content and approach; however, a better understanding about the timing of specific types of rehabilitation programs could provide important information for clinical decision making. This is especially critical in an environment of limited resources, because payers want to support rehabilitation when it can be most beneficial.

##### Research Design Considerations

This question was explored in the CER. Unfortunately, evidence was insufficient to draw conclusions. To more definitively determine if earlier initiation of multidisciplinary rehabilitation programs improve patient outcomes, controlled studies should test the effect of rehabilitation timing (in terms of functional status and/or time-since-injury) on outcomes. A few approaches could be utilized including randomized controlled trials, nonrandomized trials, and prospective cohort studies. Table 3 compares the research design considerations of these three approaches.

Table 3 Second topical research need research design considerations

Research Question: At what stage of recovery do multidisciplinary rehabilitation programs offer the best chance of improvement to patients?
Considerations | RCT | Nonrandomized Controlled Trial | Prospective Cohort
Design Description | Individual patients randomly assigned to rehabilitation programs initiated at various stages. | Individual rehabilitation centers assigned to multidisciplinary rehabilitation programs initiated at various stages. | Individuals allowed to select timing of initiating multidisciplinary rehabilitation program.
Population | Patients with sustained impairments from moderate to severe TBI; limited to closed head injuries. | Patients with sustained impairments from moderate to severe TBI; limited to closed head injuries. | Patients with sustained impairments from moderate to severe TBI; limited to closed head injuries.
Intervention | Multidisciplinary rehabilitation program begun earlier or later in recovery. | Multidisciplinary rehabilitation program begun earlier or later in recovery. | Multidisciplinary rehabilitation program begun earlier or later in recovery.
Comparator | Rehabilitation program initiated once patient medically stable. | Rehabilitation program initiated once patient medically stable. | Rehabilitation program initiated once patient medically stable.
Outcomes | Participation; quality of life | Participation; quality of life | Participation; quality of life
Timing | Followup should extend through at least one-year after initiation of rehabilitation program. | Followup should extend through at least one-year after initiation of rehabilitation program. | Followup should extend through at least one-year after initiation of rehabilitation program.
Setting | Rehabilitation center | Rehabilitation center | Rehabilitation center
Advantages for Producing a Valid Result | This design, if feasible, is likely to produce the most valid results by minimizing bias from observed and unobserved variables. However, generalizability is likely to be low. | This design is more feasible than a RCT, but validity will be hampered. It will be difficult to determine if differences are due to timing or to rehabilitation center. | This design is most feasible; however risk of confounding will be high. Investigators should be careful to collect data necessary to statistically adjust for known confounders and effect modifiers. Unknown confounders also likely to be an issue. Generalizability should be high.
Resource use, size and duration | Likely necessary to recruit large samples and follow for significant length of time to insure adequate power; Intervention is also resource intensive involving multidisciplinary rehabilitation teams. | Similar to RCT | Sample size will need to be larger than experimental designs given heterogeneity of population and number of confounding/effect modifying variables. Investigators should perform power calculations.
Ethical, legal, and social issues | Ethical challenges exist. Cognitive and behavioral impairment are a common TBI impairment. Additionally, earlier rehabilitation may be seen as superior. | If standard timing of rehabilitation differs across rehabilitation centers, recruitment should not be difficult. | No major ethical or legal challenges.
Availability of data/ability to recruit | Poor. Intervention requires significant time commitment; patients may be unwilling to be randomized to later rehabilitation program. | Better than RCT, however same challenges remain. | No major challenges to recruitment.

Abbreviations: RCT = randomized controlled trial; TBI = traumatic brain injury

#### Third Topical Research Need

[underlined: Research Question:] Are benefits received from multidisciplinary rehabilitation programs sustained over the long term?

a. What level and type of followup care allows for maintenance or prevents deterioration of rehabilitation gains at given time periods postrehabilitation?

The last identified research need also relates to timing. Our stakeholders were very concerned about improving evidence assessing whether and how TBI patients can maintain the gains made in rehabilitation. The CER addressed this question and found some evidence that rehabilitation gains were sustained in the few studies that included longer term followup. However, the strength of this evidence was low, timeframes rarely went beyond 1-year and study results may have limited applicability. Stakeholders suggested that followup care is beneficial to maintaining rehabilitation gains, but little is known about how and why these benefits are conferred. None of the rehabilitation programs we examined for the CER had formal followup rehabilitation components. Additional research to examine the benefits of followup rehabilitation sessions would inform decisionmaking.

##### Research Design Considerations

Table 4 compares the research design considerations of these three approaches. Research design considerations are similar to those addressing the previous research need about rehabilitation timing.

Table 4 Third topical research need research design considerations

Research Question: Sustainability & Followup: Are benefits received from multidisciplinary rehabilitation programs sustained over the long-term?; a. What level and type of followup care allows for maintenance or prevents deterioration of rehabilitation gains at given time periods post rehabilitation?
Considerations | RCT | Nonrandomized Controlled Trial | Prospective Cohort
Design Description | Individual patients randomly assigned to rehabilitation programs with varying levels of followup. | Individual rehabilitation centers assigned to multidisciplinary rehabilitation programs with varying levels of followup. | Individuals select level of followup included with multidisciplinary rehabilitation program.
Population | Patients with sustained impairments from moderate to severe TBI; limited to closed head injuries. | Patients with sustained impairments from moderate to severe TBI; limited to closed head injuries. | Patients with sustained impairments from moderate to severe TBI; limited to closed head injuries.
Intervention | Multidisciplinary rehabilitation program with varying levels of followup. | Multidisciplinary rehabilitation program with varying levels of followup. | Multidisciplinary rehabilitation program with varying levels of followup.
Comparator | Multidisciplinary rehabilitation program with no followup. | Multidisciplinary rehabilitation program with no followup. | Multidisciplinary rehabilitation program with no followup.
Outcomes | Participation; quality of life | Participation; quality of life | Participation; quality of life
Timing | Followup should extend 2–5 years to fifteen years after program initiation. | Followup should extend 2–5 years to fifteen years after program initiation. | Followup should extend 2–5 years to fifteen years after program initiation.
Setting | Rehabilitation center | Rehabilitation center | Rehabilitation center
Advantages for Producing a Valid Result | This design, if feasible, is likely to produce the most valid results. However, generalizability is likely to be low. | This design is more feasible than a RCT, but validity will be hampered. It will be difficult to determine if differences are due to degree of followup or to rehabilitation center. | This design is most feasible; however risk of confounding will be high. Investigators should be careful to collect data necessary to statistically adjust for known confounders and effect modifiers. Unknown confounders are also likely to be an issue.
Resource use, size and duration | Likely necessary to recruit large samples and follow for significant length of time; Power calculations should be performed. Loss to followup likely to be significant. Intervention itself and monitoring fidelity to protocol are resource intensive. | Similar challenges to RCT. | Sample size will need to be larger than randomized designs given heterogeneity of population and number of confounding/effect modifying variables. Power calculations should be performed. Loss to followup likely to be significant.
Ethical, legal, and social issues | Ethical challenges exist. Cognitive and behavioral impairment are a common impairment resulting from TBI. Additionally, followup rehabilitation sessions may be seen as superior. | Fewer challenges in recruiting rehabilitation centers than individuals. | No major ethical or legal challenges.
Availability of data/ability to recruit | Poor. Intervention requires significant time commitment; patients may be unwilling to be randomized to no followup rehabilitation program. | Better than RCT, however same challenges remain. | Fewer challenges to recruitment. Patients may be unwilling to commit to no followup rehabilitation programs.

Abbreviations: RCT = randomized controlled trial; TBI = traumatic brain injury