# References

1 Brasure M, Lamberty GJ, Sayer NA, et al. Multidisciplinary Postacute Rehabilitation for Moderate to Severe Traumatic Brain Injury in Adults. Comparative Effectiveness Review No. 72. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-2007-10064-I.). AHRQ Publication No. 12-EHC101-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
2 O’Haire C, McPheeters M, Nakamoto EK, et al. Methods for Engaging Stakeholders To Identify and Prioritize Future Research Needs. Methods Future Research Needs Report No. 4. (Prepared by the Oregon Evidence-based Practice Center and the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10057-I.). AHRQ Publication No. 11-EHC044-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
3 Effective Healthcare Program. Effective Healthcare Contacts Database. 2012.
4 National Institute of Neurological Disorders and Stroke. NINDS Common Data Elements: Traumatic Brain Injury. 2012. www.commondataelements.ninds.nih.gov/TBI.aspx#tab=Data_Standards. Accessed on June 10, 2012.
5 Andrews J. Prioritization Criteria Methodology for Future Research Needs Proposals Within the EHC Program. Methods Future Research Needs Report No. 10. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No.290-2007-10065-I). Rockville, MD. Agency for Healthcare Research and Quality. January. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
6 SurveyMonkey.com LLC. Palo Alto, California, USA. 2012. www.surveymonkey.com.
7 Carey T, Sanders GD, Viswanathan M, et al. Framework for Considering Study Designs for Future Research Needs. Methods Future Research Needs Report No. 8. (Prepared by the RTI–UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
8 Pawson R, Greenhalgh T, Harvey G, et al. Realist review--a new method of systematic review designed for complex policy interventions. J Health Serv Res Policy. Jul. Suppl 1. 2005;10:21-34. [pmid: 16053581].
9 Office of Management and Budget. Standards and Guidelines for Statistical Surveys. 2006. www.whitehouse.gov/sites/default/files/omb/inforeg/statpolicy/standards_stat_surveys.pdf. Accessed on May 16, 2012.
10 Hart T. Treatment definition in complex rehabilitation interventions. Neuropsychological Rehabilitation. Dec. 2009;19(6):824-40. [pmid: 19544183].
11 Boutron I, Moher D, Altman DG, et al. Extending the CONSORT statement to randomized trials of nonpharmacologic treatment: explanation and elaboration. Ann Intern Med. 2008;148(4):295-309. [pmid: 18283207].
12 Des Jarlais DC, Lyles C, Crepaz N, et al. Improving the reporting quality of nonrandomized evaluations of behavioral and public health interventions: the TREND statement. Am J Public Health. Mar. 2004;94(3):361-6. [pmid: 14998794].