# Methods

We used a deliberative process to identify and prioritize research questions relevant to the evidence gaps identified in the recently completed draft CER “Multidisciplinary Postacute Rehabilitation for Moderate to Severe Traumatic Brain Injury in Adults.”1 Figure 2 illustrates the eight steps used to accomplish the objectives of this project.

Figure 2 Project flow

Abbreviations: CER = Comparative Effectiveness Review; FRN = Future Research Needs; PICOTS = population, intervention, comparison, outcome, timing, and setting

Figure 2 describes the flow of the project in 8 steps. Step 1 is to identify the evidence gaps from the CER. Step 2 is to form and orient the stakeholder panel. Step 3 is to translate research gaps into researchable questions. Step 4 is to elicit stakeholder feedback on those questions via conference calls and emails. Step 5 is to revise the list of research gap questions based upon the stakeholder feedback. Step 6 involves having the stakeholders prioritize the revised set of research questions, higly prioritized questions are deemed research needs. Step 7 involves the EPC team identifying research design considerations for these research needs. And Step 8 is to develop the FRN report.

## Engagement of Stakeholders

We recruited a diverse stakeholder panel whose members represented various perspectives relevant to the topic. We followed Agency for Healthcare Research and Quality (AHRQ) guidance on stakeholder engagement for recruitment and communication.2 We sought to recruit stakeholders who were actively interested in multidisciplinary rehabilitation programs for TBI impairments and who wished to help shape future research priorities. We identified potential stakeholders via several means. We sought recommendations from the CER project team, including select Key Informants, Technical Expert Panel members, and peer and public reviewers. We also identified stakeholders who were serving on panels from related AHRQ FRN projects or who were listed in the Effective Health Care Contacts Database.3

Research representatives were national experts who were familiar with: (1) evidence-based medicine; (2) the obstacles often associated with conducting well-designed research on this complex condition; and (3) interventions from the fields of physical medicine and rehabilitation, neuropsychology, and speech-language pathology.

We invited participation from representatives from organizations supporting or conducting relevant research including United States Department of Veterans Affairs, United States Department of Defense, National Institute on Disability and Rehabilitation Research, National Institute of Neurological Disorders and Stroke, the American Academy of Physical Medicine and Rehabilitation, and the American Congress of Rehabilitation Medicine. We also invited policy and payer representation from the Centers for Medicare and Medicaid Services. Many stakeholders were also involved in the CER process as Key Informants, Technical Expert Panel members, or peer reviewers. This made engaging them as stakeholders challenging, because the timing of the FRN project overlapped with finalization of the CER.

## Handling Conflicts of Interest

We collected disclosures of conflicts of interests from all stakeholders. Disclosed interests did not bar any stakeholders from participation, but allowed the Evidence-based Practice Center (EPC) to evaluate contributions based upon possible conflicts. Stakeholders used a Web-based survey to rank research questions during the prioritization exercise, thus researchers and funders were blind to the others’ stated opinions.

## Refinement of Research Questions

We provided stakeholder panel members with a preliminary set of research questions prior to conference calls. During conference calls, we sought stakeholder input to further refine the research questions (i.e., organization and wording of the questions, identification of additional research questions, and elimination of research questions with limited clinical value). To facilitate this input, we provided stakeholders in advance with background material including the draft CER executive summary. We conducted three conference calls with available stakeholders during May 2012. A total of 10 stakeholders participated in the calls. All participants provided input on the calls. We revised the preliminary questions based on these discussions, and we invited stakeholders to edit or comment on the revised set of questions.

We also revised the preliminary questions in light of recent and ongoing work. For instance, the National Institute of Neurological Disorders and Stroke Common Data Elements project for TBI4 has addressed several of the limitations we found in the current literature concerning poor reporting of patient and injury characteristics, as well as inconsistent use of valid and reliable outcomes measures. We therefore excluded those questions from the ranking process. The revised set of research questions for prioritization appears in Appendix A.

## Prioritization

We asked stakeholders to prioritize these research questions according to specified criteria based on the potential impact of future research on that question. These criteria have been operationalized into seven components specific to EPC FRN projects. These components, called “Potential Value Criteria,” are as follows5:

- Potential for significant health impact on the current and future health status of people with respect to burden of the disease and health outcomes: mortality, morbidity, and quality of life.
- Potential to reduce important inappropriate (or unexplained) variation in clinical practices known to relate to quality of care. Potential to resolve controversy or dilemmas in what constitutes appropriate health care. Potential to improve decisionmaking for patient or provider, by decreasing uncertainty.
- Potential for significant (nontrivial) economic impact related to the costs of health service: to reduce unnecessary or excessive costs; to reduce high costs due to high volume use; to reduce high costs due to high unit cost or aggregate cost. Costs may impact consumers, patients, health care systems, or payers.
- Potential risk from inaction: Unintended harms from lack of prioritization of proposed research; opportunity cost of inaction.
- Addresses inequities, vulnerable, diverse populations (including issues for patient subgroups); potential to reduce health inequities.
- Potential to allow assessment of ethical, legal, social issues pertaining to the condition.
- Potential for new knowledge (Research would not be redundant; Question not sufficiently researched, including completed and in-process research; Utility of available evidence limited by changes in practice, e.g., disease detection or evolution in technology).

We developed a Web-based survey using SurveyMonkey to collect stakeholder prioritization of the research gap questions.6 All 10 stakeholders who completed disclosure statements (no more than 9 were non-Federal employees) were invited to rank research questions identified via the stakeholder conference calls. These stakeholders numerically ranked their top three of seven methodological research questions, and their top three of six topical research questions.

Stakeholder rankings were weighted according to their assigned numerical ranking. If a stakeholder assigned a question the number one priority, that question received three points; number two ranking received two points; number three ranking received one point. Three of the five respondents misunderstood the instructions and gave identical rankings to several questions. We evaluated the order of these rankings to determine the intended highest priority questions and averaged the weighted points (e.g., if a respondent gave three questions a number one priority, we gave each of those questions two points; questions ranked as second and third priorities would get no points). We identified natural breakpoints in the weighted rankings that separated high-, moderate-, and low-priority research questions. Highly prioritized research questions were considered research needs.

We then evaluated the feasibility criteria for research needs. We framed feasibility in terms of anticipated research designs. For example, factors that affect the feasibility of conducting randomized controlled trials include the sample size needed for the outcome, the size of the available pool of potential subjects, followup duration, willingness to randomize, and applicability issues. In contrast to randomization and applicability, observational studies face feasibility issues related to measuring potential confounding or effect modifying variables.

## Research Design Considerations

We generated research design considerations for identified research needs. For methodological research needs, we provided context and described resources and research design considerations potentially useful to researchers, facilitators, and funders of this type of research. For topical research needs, we highlighted the relevant element(s) of the PICOTS (population, intervention, comparison, outcome, timing, and setting), provided context, described related ongoing research, and discussed potential research designs. Because more than one research design can be applied to an individual research need, we discussed the advantages and disadvantages of different options. These discussions were guided by a recent AHRQ report describing a framework to use in considering study designs for future research.7 We did not consult with stakeholders for input on research design considerations.