# Executive Summary

## Background

This Future Research Needs (FRN) project is a followup to the recently completed Comparative Effectiveness Review (CER) “Multidisciplinary Postacute Rehabilitation for Moderate to Severe Traumatic Brain Injury in Adults.”1 The CER was motivated by uncertainty around the effectiveness and comparative effectiveness of rehabilitation programs for adult patients with sustained impairments from moderate to severe traumatic brain injury (TBI). This FRN project aims to identify and prioritize specific gaps in the current literature about the effectiveness and comparative effectiveness of multidisciplinary rehabilitation programs for which additional research would aid decisionmakers.

We used a deliberative process to identify evidence gaps, translate gaps into researchable questions, and solicit stakeholder opinion on the importance of research questions. This report proposes specific research needs along with research design considerations that may help advance research in this field.

We adapted the analytic framework from the original draft CER (Figure A). The framework describes a process experienced by adults with sustained impairments from a moderate to severe TBI entering multidisciplinary rehabilitation programs. The review addressed important Key Questions (KQs) about how these programs are characterized (KQ 1); evaluating the evidence about the comparative effectiveness of these programs in regard to participation (KQ 2); the identification and use of minimal clinically important differences (MCIDs) for key outcomes instruments (KQ 3); the sustainability of the improvements made during rehabilitation (KQ 4); and potential harms of multidisciplinary rehabilitation programs (KQ 5).1

Figure A Analytic framework

Abbreviations: KQ = Key Question; TBI = traumatic brain injury

Figure A is the analytical model relevant to multidisciplinary postacute rehabilitation for moderate to severe traumatic brain injury. Patients enter multidisciplinary rehabilitation programs with impairments from moderate to severe traumatic brain injury. These programs or services may have adverse effects. Patients participate in these programs and immediate progress is measured by intermediate outcomes specific to particular impairements (i.e., gait, memory, aggitation). Over the longer term, TBI patients hopefully make progress in the primary outcome of community reintegration. These outcomes are also influenced by factors related to the intervention, their injuries and their pre- and post-injury characteristics.

The literature search conducted for the CER covered material indexed through January 2012. Our intent was to identify and synthesize data from relevant comparative effectiveness research on multidisciplinary rehabilitation programs to inform treatment decisions. The primary outcome of interest was participation in community life as indicated by productivity or select measures of community integration.

For KQ 1, we found that multidisciplinary postacute rehabilitation programs for impairments from moderate to severe TBI varied widely in terms of populations targeted, setting, program intensity and duration, and timing of intervention. Clear categorization of all studied interventions was not possible. However, the most frequently studied programs are those based upon the comprehensive holistic day treatment model of care. These programs maintained a similar approach and mode of delivery. Individuals were enrolled in and progressed through structured intensive day-treatment programs in small groups of individuals that received several hours of treatments per day, several days per week. Treatment was delivered largely through group sessions, while maintaining an emphasis on addressing individual needs. Emphases included self-awareness of impairments and compensatory approaches to retraining, with vocational rehabilitation another key element.

From the evidence synthesized for KQ 2, we were unable to draw broad conclusions about effectiveness or comparative effectiveness of multidisciplinary rehabilitation programs. We found that a Comparative Effectiveness Review on such complex interventions led to conclusions about the very specific populations and interventions studied:

- We found insufficient evidence assessing effectiveness for productivity or community integration.
- We found low-strength evidence that gainful employment or return to military fitness did not differ significantly at 1-year posttreatment between an 6-week inpatient hospital treatment and a 8-week limited home-based treatment. Participants were active duty military patients with closed head injuries and with relatively mild impairment levels who were treated within 3 months of injury.
- We found low-strength evidence that productivity did not differ significantly at 1 year posttreatment between closed head injury participants of functional-experiential programs and cognitive-didactic inpatient rehabilitation programs. Both programs lasted an average of just over 1 month and were delivered in Veterans Affairs rehabilitation facilities. Participants began treatment within 6 months of injury.
- We found low-strength evidence that moderate to severe TBI survivors with chronic impairments judged to need 16 weeks of intensive treatment and who were enrolled in an integrated cognitive rehabilitation program achieved higher rates of return to community-based employment, but not higher rates of community integration, than participants of standard rehabilitation immediately posttreatment.
  ○ We found low-strength evidence that rates of return to community-based employment between the two groups equalized by 6 months posttreatment (rates in the standard rehabilitation group caught up with those of the integrated cognitive rehabilitation program group).

For KQ 3, we identified no evidence establishing an MCID for the Mayo-Portland Adaptability Inventory, the outcomes instrument of most interest to us. Although we identified some evidence that established and used an MCID with the Community Integration Questionnaire, overall we observed a limited use of MCIDs in available research.

We found very few eligible studies that conducted followup assessments to determine maintenance of rehabilitation gains as addressed by KQ 4. Two studies that evaluated followup outcomes yielded highly specific conclusions:

- We found low-strength evidence that improvements in return to community-based employment and Community Integration Questionnaire scores were sustained at 6 months posttreatment.
- We found low-strength of evidence that rates of participation in competitive work achieved at 6 months posttreatment appear to be sustained at 12 months posttreatment.

Lastly, few studies on this topic addressed KQ 5, adverse effects. One study that assessed adverse effects reported that none were observed.

The evidence we reviewed emphasized the complexity of traumatic brain injuries and the interventions to rehabilitate individuals suffering from associated sustained impairments. Our review, like others, found the currently available evidence about the effectiveness and comparative effectiveness of multidisciplinary rehabilitation programs for moderate to severe TBI in adults are limited. Specifically, we found insufficient evidence to assess efficacy or effectiveness, and identified few well-designed studies to address comparative effectiveness. Applicability of those studies also appears problematic. However, our CER findings should not be misunderstood to be evidence of ineffectiveness. Rather, the findings provide justification for additional research in order to further establish understanding of these complex interventions.

To guide the development of additional comparative effectiveness research on this topic, this FRN project aims to identify specific evidence gaps and prioritize FRNs with research design considerations likely to advance the field.

## Methods

We used a deliberative process to identify and prioritize research questions relevant to the KQs addressed in the CER.1 Figure B illustrates the eight steps used to accomplish the objectives of this project.

Figure B Project flow

Abbreviations: CER = Comparative Effectiveness Review; FRN = Future Research Needs; PICOTS = population, intervention, comparison, outcome, timing, setting.

Figure B describes the flow of the project in 8 steps. Step 1 is to identify the evidence gaps from the CER. Step 2 is to form and orient the stakeholder panel. Step 3 is to translate research gaps into researchable questions. Step 4 is to elicit stakeholder feedback on those questions via conference calls and emails. Step 5 is to revise the list of research gap questions based upon the stakeholder feedback. Step 6 involves having the stakeholders prioritize the revised set of research questions, higly prioritized questions are deemed research needs. Step 7 involves the EPC team identifying research design considerations for these research needs. And Step 8 is to develop the FRN report.

First, we translated the research gaps identified in the CER into research questions. Second, we assembled a diverse stakeholder panel with representation from various perspectives relevant to the topic. Invited research representatives were national experts who were familiar with: (1) evidence-based medicine; (2) the obstacles often associated with conducting well-designed research on this complex condition; and (3) interventions from the fields of physical medicine and rehabilitation, neuropsychology, and speech-language pathology. We invited participation from representatives from organizations supporting or conducting relevant research, including the U.S. Department of Veterans Affairs, U.S. Department of Defense, National Institute on Disability and Rehabilitation Research, National Institute of Neurological Disorders and Stroke, the American Academy of Physical Medicine and Rehabilitation, and the American Congress of Rehabilitation Medicine. We also invited policy and payer representation from the Centers for Medicare and Medicaid Services. Finally, we engaged providers and consumers, because the decisional dilemmas faced by these groups are critical to identifying and prioritizing research questions.

We first held conference calls with stakeholders to refine the draft research questions. Based upon these conversations and an assessment of recent and ongoing work, we revised our initial list of research questions. This revision included separating the questions into categories (methodological research questions that need to be addressed to enhance the usefulness of current effectiveness research, and topical research questions that have not been sufficiently addressed in the current literature). We sent this list of research questions to stakeholders for ranking. Stakeholders numerically ranked their top three methodological research questions from a total of seven and their top three topical research questions from a total of six.

Rankings were weighted based upon stakeholder numerical ordering of questions. Based upon natural breakpoints in the weighted rankings, we determined high-, moderate-, and low-priority research questions. High priority questions were deemed research needs. We then identified and discussed research design considerations for those identified research needs.

## Results

### Prioritization Results

We analyzed weighted rankings for stakeholders participating in the Web-based prioritization process. Of the 10 stakeholders invited to rank research questions, 5 ranked methodological questions and 4 ranked topical questions.

#### Methodological Research Needs

A natural breakpoint in weighted rankings revealed two methodological research needs. Addressing methodological research needs will enhance the utility and translation of current and future research on multidisciplinary rehabilitation programs for sustained impairments from moderate to severe TBI in adults:

- What outcomes of multidisciplinary rehabilitation are most important to:
  ○ Patients
  ○ Families
  ○ Payers
- Which [underlined: patient characteristics] confound/modify effectiveness of rehabilitation programs?

Methodological research needs pertain to identifying outcomes that are important to patients, families, and payers, and to identifying patient characteristics that influence response to rehabilitation.

##### Considerations for Potential Research Designs

There are several ways that these methodological research needs could be addressed. Systematic reviews, epidemiological studies, and/or qualitative research would all assist in improving the understanding with regard to valued outcomes and factors than confound or modify the effect of TBI rehabilitation. One way to identify specific outcomes valued by patients may be to review the literature or secondary databases about TBI rehabilitation programs that use shared decisionmaking or goal setting among patients, families, and providers. Qualitative research would also be useful. Focus groups, for example, with representatives of patients, families, and payers – in separate focus groups- would help to identify these outcomes. Several patient and family focus groups would be necessary due to the wide range of impairment types and levels resulting from moderate to severe TBI. Preferred outcomes are likely associated with patient impairment types and levels at rehabilitation initiation.

Patient characteristics associated with the effectiveness of rehabilitation programs could be identified through similar methods. This process would benefit first from a systematic literature review. Several studies that examine patient characteristics and their influence on outcomes are available. A systematic review is not likely to provide the complete picture of confounding and effect modifying factors. Analysis of secondary databases and post hoc analysis of effectiveness studies establishing potential relationships between patient characteristics and patient outcomes should be included in such a systematic review. By definition, multidisciplinary rehabilitation programs involve several provider types; therefore a multidisciplinary approach to consensus development is essential. Participants should include clinical experts and researchers with expertise in clinical outcomes, epidemiology, biostatistics, and health services research.

##### Topical Research Needs

Topical research needs primarily addressed the PICOTS (population, intervention, comparison, outcome, timing, and setting) elements of interventions, outcomes, and timing; a breakpoint in weighted rankings revealed three prominent topical research needs. Addressing these issues will enhance understanding of efficacy and comparative effectiveness, which was limited in the draft CER.

##### First Topical Research Need

- Which multidisciplinary rehabilitation programs are “promising practices?”
- What benefits are experienced by patients participating in various multidisciplinary rehabilitation programs?
- What outcomes appear to be most improved by various multidisciplinary rehabilitation programs?
- Which patients (subgroups) appear to benefit most by various multidisciplinary rehabilitation programs?
- What kinds of harms are experienced by patients participating in various multidisciplinary rehabilitation programs?

###### Considerations for Potential Research Designs

The draft CER and peer review of that draft emphasized the limited value of rigorous Comparative Effectiveness Reviews on this topic given the complexity of rehabilitation programs for TBI impairments and the current status of this literature. As topics for Comparative Effectiveness Reviews have expanded beyond pharmaceutical interventions, alternative approaches have been proposed to synthesize research on complex interventions (characterized as programs in which effects are dependent on context and implementation). These methods may be an option better suited to such topics. These reviews are rigorous systematic reviews, but focus more on explaining how, when, and why certain interventions may work or not work. This approach to a systematic review provides improved understanding of interventions and their populations and therefore may be a good fit for complex interventions such as rehabilitation.

##### Second Topical Research Need

- Timing: At what stage of recovery do multidisciplinary rehabilitation programs offer patients the best chance of improvement?

Understanding the timing of enrollment in rehabilitation programs likely to maximize benefits received from rehabilitation is another research need. This question was addressed by the CER KQs. However, data was too limited assess the influence of rehabilitation program timing. This is especially critical in an environment of limited resources, because payers want to support rehabilitation when it can be most beneficial.

###### Considerations for Potential Research Designs

A definitive test of the relationship between rehabilitation timing (in terms of functional status and/or time-since-injury) and outcomes could be attained through experimental studies. RCTs should provide the most valid results. However, given the heterogeneity in this population requiring restrictive inclusion/exclusion criteria, results would have limited generalizability. Additionally, the limited feasibility and ethical concerns of conducting RCTs in this population suggest that prospective cohort studies might best address this research question. These studies should be carefully conducted by measuring all potentially confounding variables necessary to statically adjust for selection bias and be designed with adequate power.

##### Third Topical Research Need

- Sustainability and followup: Are benefits received from multidisciplinary rehabilitation programs sustained over the long term?
- What level and type of followup care allows for maintenance or prevents deterioration of rehabilitation gains at given time periods postrehabilitation?

The last identified research need also relates to timing. Our stakeholders were very concerned about improving evidence assessing whether and how TBI patients can maintain the gains made in rehabilitation. The CER addressed this question and found some evidence that rehabilitation gains were sustained in the few studies that included longer term followup. However, the strength of this evidence was low, timeframes rarely went beyond 1 year and study results may have limited applicability. Stakeholders suggested that followup care is beneficial to maintaining rehabilitation gains, but little is known about how and why these benefits are conferred. None of the rehabilitation programs we examined for the CER had formal followup rehabilitation components. Additional research to examine the benefits of followup rehabilitation sessions would inform decisionmaking.

###### Considerations for Potential Research Designs

Considerations similar to those mentioned in regard to topical research need number 2 would assist investigators in designing studies to test the hypothesized relationship of rehabilitation on long-term outcomes and followup rehabilitation on patient outcomes.

## Discussion

This FRN project refined and prioritized research needs relevant to the KQs addressed in the draft CER, “Multidisciplinary Postacute Rehabilitation for Moderate to Severe Traumatic Brain Injury in Adults.”1 We conducted a deliberative process to refine and expand research gaps identified in the CER through conversations with stakeholders who represented various perspectives and expertise on the topic. This process identified seven methodological and six topical research questions thought to address identified evidence gaps. We then asked stakeholders to rank research questions according to their potential impact. The highly ranked questions were deemed research needs. Results from the ranking process revealed two methodological and three topical research needs.

Addressing methodological research needs will enhance the utility and comparability of future studies of multidisciplinary rehabilitation for moderate to severe TBI. These needs involve identifying patient centered outcomes and patient characteristics associated with response to rehabilitation.

Identified topical research needs demonstrate the importance of an enhanced understanding of (1) how and why multidisciplinary rehabilitation programs benefit specific types of patients and (2) the timing of rehabilitation that may be most beneficial and how to maintain or prevent deterioration after rehabilitation. Future studies of multidisciplinary rehabilitation programs should be designed to pay close attention to reducing bias as much as possible for the selected research design. Studies should be adequately powered to test hypothesized relationships, including among subgroups.

While a strength of this project is the intended variety of perspectives brought by broad stakeholder participation, we were not able to collect a representative perspective from a larger sample of stakeholders and had a low response rate to our stakeholder invitations and ranking process. This is a major limitation. The stakeholders participating in this project represented various perspectives on multidisciplinary rehabilitation programs for TBI. However, the prioritized research needs reflect the opinions of these stakeholders and may not be applicable to the broader population of stakeholders on this topic. This CER and related FRN project overlapped with several other projects tapping the same group of stakeholders and could explain the limited availability and interest in participation. Stakeholder discussions emphasized the need for federal agencies to work together to understand activities within each agency surrounding this topic.

## Conclusions

This FRN project identified several research needs thought relevant by a select group of stakeholders to move the field forward. The first research need was not directly addressed in our CER and therefore may need a systematic review to determine more specifically what these research gaps are:

- What outcomes of multidisciplinary rehabilitation are most important to:
  ○ Patients
  ○ Families
  ○ Payers

Remaining research needs were questions that would have been covered in the original CER, but evidence was insufficient and/or conclusions had limited applicability:

- Which [underlined: patient characteristics] confound/modify effectiveness of rehabilitation programs?
- Which multidisciplinary rehabilitation programs are “promising practices?”
  ○ What benefits are experienced by patients participating in various multidisciplinary rehabilitation programs?
  ○ What outcomes appear to be most improved by various multidisciplinary rehabilitation programs?
  ○ Which patients (subgroups) appear to benefit most by various multidisciplinary rehabilitation programs?
  ○ What kinds of harms are experienced by patients participating in various multidisciplinary rehabilitation programs?
- Timing: At what stage of recovery do multidisciplinary rehabilitation programs offer the best chance of improvement to patients?
- Sustainability and Followup: Are benefits received from multidisciplinary rehabilitation programs sustained over the long term?

What level and type of followup care allows for maintenance of or prevents deterioration of rehabilitation gains at given time periods postrehabilitation?

## References

1 Brasure M, Lamberty GJ, Sayer NA, et al. Multidisciplinary Postacute Rehabilitation for Moderate to Severe Traumatic Brain Injury in Adults. Comparative Effectiveness Review No. 72. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-2007-10064-I.) AHRQ Publication No. 12-EHC101-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.