# Discussion

This FRN project refined and prioritized research needs relevant to the KQs addressed in the draft CER, “Multidisciplinary Postacute Rehabilitation for Moderate to Severe Traumatic Brain Injury in Adults.”1 We conducted a deliberative process to refine and expand research gaps identified in the CER through conversations with stakeholders who represented various perspectives and expertise on the topic. This process identified seven methodological and six topical research questions thought to address identified evidence gaps. We then asked stakeholders to rank research questions according to their potential impact. The highly ranked questions were deemed research needs. Stakeholders prioritized two methodological and three topical research needs.

Addressing methodological research needs will enhance the utility and comparability of future studies of multidisciplinary rehabilitation for moderate to severe TBI. These needs involve identifying patient centered outcomes and patient characteristics associated with response to rehabilitation.

Identified research needs demonstrate the importance of an enhanced understanding of (1) how and why multidisciplinary rehabilitation programs benefit specific types of patients and (2) the timing of rehabilitation that may be most beneficial. Future studies of multidisciplinary rehabilitation programs should be designed to pay close attention to reducing bias as much as possible for the selected research design. Studies should be adequately powered to test hypothesized relationships, including among subgroups.

While a strength of this project is the intended variety of perspectives brought by broad stakeholder participation, we were not able to collect a representative perspective from a larger sample of stakeholders and had a low response rate to our stakeholder invitations and ranking process. This is a major limitation. The stakeholders participating in this project represented various perspectives on multidisciplinary rehabilitation programs for TBI. However, the prioritized research needs reflect the opinions of these stakeholders and may not be applicable to the broader population of stakeholders on this topic.

Our stakeholder panel was also limited in size by standards and guidelines for statistical surveys administered by the Office of Management and Budget. These guidelines require compliance with the Paperwork Reduction Act and Information Collections Policy (44 USC 3501-3520).9 The Act was designed to (1) minimize the paperwork burden on the public; (2) assure that high quality data are obtained, and (3) minimize costs. The Act requires special approval for projects that wish to include more than nine non-government participants; however, the approval process exceeded the length of time available to complete this FRN project.

Finally, this CER and related FRN project overlapped with several other projects that tapped the same group of stakeholders. This could explain the limited availability and interest in participation. Stakeholder discussions emphasized the need for federal agencies to work together to understand ongoing activities within each agency to avoid duplication of effort.

Future studies of multidisciplinary rehabilitation programs should seek to reduce bias as much as possible for the particular research design used. Literature examined for the draft CER rarely provided adequate and consistent measurement and reporting of variables thought to confound or modify the effect of multidisciplinary rehabilitation programs, but because the ongoing Common Data Element efforts appear to sufficiently address this concern, we did not include this methodological research question in our list prioritized by stakeholders. One study currently underway (NCT01565551) is testing the use of Common Data Element recommendations. Investigators interested in this topic should follow these ongoing efforts. Further, studies should be adequately powered to test hypothesized relationships. Power calculations that take into consideration any subgroup analysis that may be performed are especially encouraged.

Additionally, the quality of comparative effectiveness research on multidisciplinary rehabilitation for impairments from moderate to severe TBI could be greatly improved through more precise intervention definitions and the construction of a topology of the various approaches to multidisciplinary rehabilitation programs. Guidance is available to researchers regarding how to better describe interventions in order to enhance the quality of comparative effectiveness studies and permit replicability.10 Interventions that are founded on theory, manualized, and utilize fidelity checks to ensure proper implementation are most likely to result in studies with valid results. Reporting guidance in published comparativeness studies with particular attention to intervention definition is also available. The Consolidated Standards of Reporting Trials (CONSORT) statement for nonpharmacologic interventions could guide the data collected and reported in effectiveness research.11 The CONSORT statement specifically describes elements of interventions that should be included. The Transparent Reporting of Evaluations with Nonrandomized Designs (TREND) statement, designed for public health interventions, also provides a good explanation of the types of information about interventions that should be captured and reported.12

Lastly, one stakeholder’s comment provided in the ranking survey illustrates the context of current state of research on this topic. This stakeholder felt that ranking the topical research questions was not possible, commenting:

“I have trouble getting invested in any of these questions in the current real world in which we live. Based on this review, we have very tenuous evidence of the effectiveness of such programs in the first place, and no typology of the programs being evaluated to even know whether they exist in categories or each is idiosyncratically developed to meet the needs of the specific patients and payers who happen to be present locally. The above are all much more nuanced questions that I don’t believe can be answered in the foreseeable future. The evidence to answer them does not exist and it will require a major investment in primary treatment research to generate enough evidence to conduct productive meta-analyses or CER reviews. I think there is limited value to listing the research questions that in theory need to be answered when they are so far removed from the research currently being supported.”

This comment mirrors another stakeholder discussion suggesting that preliminary research questions focused on the effectiveness of rehabilitation programs were beyond the current science on the topic. This stakeholder felt that a better understanding of individual interventions is first required before considering programs as a whole. In any case, an improved understanding of multidisciplinary programs and the specific components of these programs appears imperative to advance this field. While current efforts are underway to enhance this understanding, TBI rehabilitation would benefit from a coordinated research agenda and funding to support additional efforts to enhance our understanding of multidisciplinary rehabilitation programs.