# Conclusions

This FRN project identified several research needs thought relevant by a select group of stakeholders to move the field forward. The first research need was not directly addressed in our CER and therefore may need a systematic review to determine more specifically what these research gaps are:

- What outcomes of multidisciplinary rehabilitation are most important to:
  ○ Patients
  ○ Families
  ○ Payers

Remaining research needs were questions that would have been covered in the original CER, but evidence was insufficient and/or conclusions had limited applicability:

- Which [underlined: patient characteristics] confound/modify effectiveness of rehabilitation programs?
- Which multidisciplinary rehabilitation programs are “promising practices?”
  ○ What benefits are experienced by patients participating in various multidisciplinary rehabilitation programs?
  ○ What outcomes appear to be most improved by various multidisciplinary rehabilitation programs?
  ○ Which patients (subgroups) appear to benefit most by various multidisciplinary rehabilitation programs?
  ○ What kinds of harms are experienced by patients participating in various multidisciplinary rehabilitation programs?
- Timing: At what stage of recovery do multidisciplinary rehabilitation programs offer the best chance of improvement to patients?
- Sustainability and followup: Are benefits received from multidisciplinary rehabilitation programs sustained over the long term?
  ○ What level and type of followup care allows for maintenance of or prevents deterioration of rehabilitation gains at given time periods postrehabilitation?