# Background

## Context

This Future Research Needs (FRN) project is a followup to the recently completed Comparative Effectiveness Review (CER) “Multidisciplinary Postacute Rehabilitation for Moderate to Severe Traumatic Brain Injury in Adults.”1 The CER was motivated by uncertainty around the effectiveness and comparative effectiveness of rehabilitation programs for adult patients with sustained impairments from moderate to severe traumatic brain injury (TBI). This FRN project aims to identify and prioritize specific gaps in the current literature about the effectiveness and comparative effectiveness of multidisciplinary rehabilitation programs for which additional research would aid decisionmakers. We used a deliberative process to identify evidence gaps, translate gaps into researchable questions, and solicit stakeholder opinion on the importance of research questions. This report proposes specific research needs along with research design considerations that could advance research in this field.

Our FRNs project identifies research needs within the scope of the CER. We used an analytical framework (Figure 1) to construct the following Key Questions (KQs):

KQ 1 How have studies characterized multidisciplinary postacute rehabilitation for TBI in adults?
KQ 2 What is the effectiveness and comparative effectiveness of multidisciplinary postacute rehabilitation for TBI?
  a. Do effectiveness and comparative effectiveness vary by rehabilitation timing, setting, intensity, duration, or composition?
  b. Do effectiveness and comparative effectiveness vary by injury characteristics?
  c. Do effectiveness and comparative effectiveness vary by patient characteristics, preinjury or postinjury?
KQ 3 What evidence exists to establish a minimum clinically important difference in community reintegration as measured by the Mayo-Portland Adaptability Inventory-4 for postacute rehabilitation for TBI in adults?
KQ 4 Are improvements in outcomes achieved via multidisciplinary postacute rehabilitation for TBI sustained over time?
KQ 5 What adverse effects are associated with multidisciplinary postacute rehabilitation for TBI?

Figure 1 Analytic framework

Abbreviations: KQ = Key Question; TBI = traumatic brain injury

Figure 1 is the analytical model relevant to multidisciplinary postacute rehabilitation for moderate to severe traumatic brain injury. Patients enter multidisciplinary rehabilitation programs with impairments from moderate to severe traumatic brain injury. These programs or services may have adverse effects. Patients participate in these programs and immediate progress is measured by intermediate outcomes specific to particular impairements (i.e., gait, memory, aggitation). Over the longer term, TBI patients hopefully make progress in the primary outcome of community reintegration. These outcomes are also influenced by factors related to the intervention, their injuries and their pre- and post-injury characteristics.

## Comparative Effectiveness Review Findings

The literature search conducted for the CER covered material indexed through January 2012. Our intent was to identify and synthesize data from relevant comparative effectiveness research on multidisciplinary rehabilitation programs to inform treatment decisions. The primary outcome of interest was participation in community life as indicated by productivity or select measures of community integration.

For KQ 1, we found that multidisciplinary postacute rehabilitation programs for impairments from moderate to severe TBI varied widely in terms of populations targeted, setting, program intensity and duration, and timing of intervention. Clear categorization of all studied interventions was not possible. However, the most frequently studied programs are those based upon the comprehensive holistic day treatment model of care. These programs maintained a similar approach and mode of delivery. Individuals were enrolled in and progressed through structured intensive day-treatment programs in small groups of individuals that received several hours of treatments per day, several days per week. Treatment was delivered largely through group sessions, while maintaining an emphasis on addressing individual needs. Emphases included self-awareness of impairments and compensatory approaches to retraining, with vocational rehabilitation another key element.

From the evidence synthesized for KQ 2, we were unable to draw broad conclusions about effectiveness or comparative effectiveness of multidisciplinary rehabilitation programs. We found that a Comparative Effectiveness Review on such complex interventions led to conclusions about the very specific populations and interventions studied:

- We found insufficient evidence assessing effectiveness for productivity or community integration.
- We found low-strength evidence that gainful employment or return to military fitness did not differ significantly at 1 year posttreatment between an 6-week inpatient hospital treatment and a 8-week limited home-based treatment. Participants were active duty military patients with closed head injuries and with relatively mild impairment levels who were treated within 3 months of injury.
- We found low-strength evidence that productivity did not differ significantly at 1 year posttreatment between closed head injury participants of functional-experiential programs and cognitive-didactic inpatient rehabilitation programs. Both programs lasted an average of just over 1 month and were delivered in Veterans Affairs rehabilitation facilities. Participants began treatment within 6 months of injury.
- We found low-strength evidence that moderate to severe TBI survivors with chronic impairments judged to need 16 weeks of intensive treatment and who were enrolled in an Integrated Cognitive Rehabilitation Program achieved higher rates of return to community-based employment, but not higher rates of community integration, than participants of standard rehabilitation immediately posttreatment.
  ○ We found low-strength evidence that rates of return to community-based employment between these two groups equalized by 6 months posttreatment (rates in the standard rehabilitation group caught up with those of the Integrated Cognitive Rehabilitation Program group).

For KQ 3, we identified no evidence establishing a minimal clinically important difference (MCID) for the Mayo-Portland Adaptability Inventory, the outcomes instrument of most interest to us. Although we identified some evidence that established and used an MCID with the Community Integration Questionnaire, overall we observed a limited use of MCIDs in available research.

We found very few eligible studies that conducted followup assessments to determine maintenance of rehabilitation gains as addressed by KQ 4. Two studies that evaluated followup outcomes yielded highly specific conclusions:

- We found low-strength evidence that improvements in return to community-based employment and Community Integration Questionnaire scores were sustained at 6 months posttreatment.
- We found low-strength of evidence that rates of participation in competitive work achieved at 6 months posttreatment appear to be sustained at 12 months posttreatment.

Lastly, few studies on this topic addressed KQ 5, adverse effects. One study that assessed adverse effects reported that none were observed.

The evidence we reviewed emphasized the complexity of traumatic brain injuries and the interventions to rehabilitate individuals suffering from associated sustained impairments. Our review, like others, found that currently available evidence about the effectiveness and comparative effectiveness of multidisciplinary rehabilitation programs for moderate to severe TBI in adults is limited. Specifically, we found insufficient evidence to assess efficacy or effectiveness, and identified few well-designed studies to address comparative effectiveness. Applicability of those studies also appears problematic. However, our CER findings should not be misunderstood to be evidence of ineffectiveness, but should instead provide justification for additional research in order to further establish understanding of these complex interventions.

To guide the development of additional comparative effectiveness research on this topic, this FRN project aims to identify specific evidence gaps and prioritize FRNs with research design considerations likely to advance the field.

## Evidence Gaps and Research Question Development

As with much of the research on functional therapies, many studies of multidisciplinary rehabilitation for adults with moderate to severe TBI exhibited problems with design and conduct. Our original report included general recommendations to fill evidence gaps on this topic. To elaborate on these recommendations, we translated specific evidence gaps into research questions. Research questions are presented in two categories: methodological research questions that need to be addressed to enhance the usefulness of current topical research, and topical research questions not adequately addressed within the current literature:

### Methodological Research Questions

1. What taxonomies of moderate to severe TBI impairments should be used in research to encourage consistency and comparability across studies?
2. How should the severity of specific impairments be assessed and reported in effectiveness research to encourage consistency and comparability across studies?
3. How should the severity of overall impairments be assessed and reported in effectiveness research to encourage consistency and comparability across studies?
4. What framework describing postacute rehabilitation for moderate to severe TBI should be used in research to encourage consistency and comparability across studies?
5. What taxonomy for postacute rehabilitation for moderate to severe TBI should be used in research to encourage consistency and comparability across studies?
6. How should interventions be defined to encourage consistency and comparability across studies and support replicability?
  a. Comprehensive programs
  b. Individual components of comprehensive programs
7. What are the valid and reliable instruments used to measure patient-centered outcomes?
  a. What is the MCID for each of these valid and reliable instruments?
  b. What cut points should be used to describe clinically meaningful categories in the scale scores created by these instruments?
  c. What are the advantages and disadvantages to using MCIDs in research on this topic?
8. What are the valid and reliable instruments used to measure intermediate outcomes when evaluating the effectiveness and comparative effectiveness of individual components of comprehensive programs or single-impairment therapies?
9. Which intermediate outcomes meet criteria for surrogate patient-centered outcomes?
10. What confounding variables (e.g., family support, patient engagement, concomitant therapies, comorbidities), and effect modifiers (e.g., education level, preinjury employment status, age group) should be addressed and reported in effectiveness research?
11. What specific data should be reported in effectiveness studies?

### Topical Research Questions

1. What is the effectiveness of postacute rehabilitation for moderate to severe TBI?
2. What is comparative effectiveness of postacute rehabilitation for moderate to severe TBI?
3. What is the marginal benefit from specific components of comprehensive programs (e.g., case management) delivered in the appropriate stage of recovery?
4. Do sustained changes in patient-centered outcomes differ by the duration, intensity, and frequency of examined interventions?
5. Which patient characteristics are associated with patient-centered outcomes (comorbidities age, functional status, time since injury, impairment type, concomitant treatments, etc.)?
6. How do patient-centered outcomes differ depending on the setting in which rehabilitation is provided?