# Relevant Ongoing Studies

Study ID | Title | Purpose
NCT01334398 | A Health & Wellness Intervention for Individuals With Traumatic Brain Injury (TBI) | The primary goal of the proposed study is to evaluate the efficacy of a replicable community-based group intervention, designed to address both general wellness and specific TBI health-related issues. Emphasis is placed on goal setting to develop healthy habits, utilizing problem solving strategies, learning means of maintaining progress and setting new goals. Facilitators will utilize approaches aimed at maximizing participant self-efficacy, reducing barriers to health promotion, and developing personal resources. A randomized wait-list control group design will be used to evaluate the efficacy of the intervention. It is hypothesized that individuals with TBI who participate in the intervention group will report increased health promoting behaviors, health related self-efficacy, health-related quality of life, level of participation, and greater perceived wellness and satisfaction with life as compared with the control group.
NCT00233129 | Improving Executive Functions After Traumatic Brain Injury (TBI): A Clinical Trial of the “Executive Plus” Program | This is a randomized clinical trial which compares a standard day treatment program for individuals with TBI with the “Executive Plus” program; the latter emphasizes training of attention, emotional self-regulation and problem solving. The goal of the Executive Plus program is to maximize executive functioning, as well as the long-term outcomes of community participation and satisfaction with daily life.
NCT00627237 | Improving Executive Functioning After Traumatic Brain Injury (TBI): A Trial of the “Short Term Executive Plus” Program | The purpose of this study is to determine the efficacy of an intensive short term cognitive rehabilitation program aimed towards improving executive functioning in individuals with traumatic brain injury (TBI).
NCT00676182 | Telerehabilitation for Operation Iraqi Freedom/Operation Enduring Freedom (OIF/OEF) Returnees With Combat-Related Telerehab for Traumatic Brain Injury | The scientific objective of this program is to meet the rehabilitation needs of combat wounded veterans with mild to moderate Traumatic Brain Injury (TBI) via telerehabilitation and determine the effect of this modality of care on patients’ physical health and outcomes including function and community participation. We will also evaluate the benefits and limitations of rehabilitation using telehealth from the veteran and caregiver perspectives and evaluate the impact of rehabilitation via telehealth on Veterans Affairs health care facility use.
NCT00704067 | Improving Work Outcomes for Veterans With Traumatic Brain Injury | The 12-month study will investigate a cognitive training augmentation of supported employment to improve cognitive performance and work outcomes, which are expected to result in improved quality of life and community integration for veterans with mild to moderate traumatic brain injuries. The primary hypothesis is that compared with veterans who receive enhanced supported employment, those who receive supported employment plus cognitive training will work more weeks during the 12 months.
NCT00714428 | | Development of Quality of Life Tool for TBI (TBI QOL) O1: Identify a parsimonious set of domains that capture HRQOL in deployment-related TBI. O2: Construct and refine clinically-relevant HRQOL of life item banks for deployment-related TBI, in order to O3: Utilize Item Response Theory methodology to refine and calibrate targeted and generic item banks for use with O4: Develop a short form, refining item sets and developing algorithms for future development of a computerized
NCT01020318 | Evaluation of Outcome Measures for Patients Diagnosed With Traumatic Brain Injury | To evaluate potential test instruments in patients with TBI. To evaluate patient tolerance of an extensive battery of assessments and the time required to complete the assessments. To improve staff competencies on new or novel assessments of the TBI patient population
NCT01132898 | Long-term Clinical Correlates of Traumatic Brain Injury | The primary objective is to contribute to the understanding of non-penetrating traumatic brain injury (TBI) through the description of the relationships between neuroimaging, hematological, and extensive functional/cognitive phenotyping measures. We will generate natural history data for cohort-based comparisons and to serve as the basis for future hypothesis-driven protocols. In addition, we will create and test a series of new taxonomies to describe TBI severity and predict outcome.
NCT01138020 | Cognitive Rehabilitation of Blast Traumatic Brain Injury (TBI) | The purpose of this study is to investigate the efficacy of a structured rehabilitation program on cognitive function and quality of life in individuals with blast-induced traumatic brain injury (bTBI).
NCT01158781 | Restoration of Life Role Participation Through Integrated Cognitive and Motor Training for Individuals With Traumatic Brain Injury (TBI) | The purpose of this study is to restore life role participation for those with TBI by customizing, applying, and testing integrated cognitive and motor training protocols that were successful in populations with impairments similar to TBI. The treatment protocols are based on principles of brain plasticity and re-learning, required to restore cognitive and motor function. The intervention targets an array of impairments that are obstacles to life role participation. These include cognitive attention and executive control; motor control for upper limb function; balance and gait; and cognitive executive control of simultaneous cognitive and motor tasks required by everyday tasks. The intervention utilizes training specificity, framing the intervention within functional task and life role activity component practice.
NCT01166386 | Acute Neurobehavioral Program for Improving Functional Status After TBI | Our long-term goal is to lessen these burdens through improving the functional status of patients with TBI by providing an evidence-based, comprehensive, brief, acute-care intervention, First Steps Acute Neurobehavioral and Cognitive Intervention (FANCI). The 10-sesson, manualized FANCI Program will be tested in a controlled, randomized study.
NCT01420939 | Developing Therapies for Traumatic Brain Injury | To collect medical information from people with recent traumatic brain injury and compare this information to that of healthy volunteers and of persons who have had injuries to other parts of their bodies besides their heads (such as broken bones, orthopedic injuries, after surgery).
NCT01565551 | Transforming Research and Clinical Knowledge in Traumatic Brain Injury (TRACK-TBI) | Transforming Research and Clinical Knowledge in Traumatic Brain Injury (TRACK-TBI): The global aim of this proposal is to test and refine Common Data Elements (CDEs), neuroimaging standards, and best practices for genetics and proteomics in Traumatic Brain Injury (TBI) studies. Testing and validating of TBI-CDEs will be performed in a multi-center prospective observational study with 3 TBI Centers (San Francisco General Hospital, University of Pittsburgh Medical Center, University Medical Center Brackenridge) and a TBI Rehabilitation Center (Mount Sinai Rehabilitation Center). The investigators will create and expand existing data repositories for patient demographics, neuroimaging, plasma biomarkers, genetics, and multivariate outcomes thereby providing researchers and clinicians with the infrastructure to establish multidisciplinary, multicenter research networks and improve clinical research in the TBI field.