# Search Strategy for Ongoing Studies

Advanced search for intervention and non-intervention studies on ClinicalTrials.gov

‘Traumatic brain’ in the condition field