# Research Questions for Prioritization

## Methodological Research Questions

1. How should patient readiness for multidisciplinary rehabilitation programs be measured?
2. What outcomes of multidisciplinary rehabilitation are most important to:
  - Patients
  - Families
  - Payers
3. MCIDs
  - What are the minimum clinically important differences (MCIDs) for outcomes instruments?
  - What are the advantages and disadvantages to using MCIDs in research on this topic?
  - Should they be used to measure program effectiveness?
4. Which intermediate outcomes adequately predict patient-centered outcomes (surrogate outcomes)?
5. Which [underlined: injury characteristics] confound/modify effectiveness of rehabilitation programs?
6. Which [underlined: patient characteristics] confound/modify effectiveness of rehabilitation programs?
7. What typology should be used to classify multidisciplinary rehabilitation programs?

## Topical Research Questions

1. Which multidisciplinary rehabilitation programs are “promising practices?”
  a. What benefits are experienced by patients participating in various multidisciplinary rehabilitation programs?
  b. What outcomes appear to be most improved by various multidisciplinary rehabilitation programs?
  c. Which patients (subgroups) appear to benefit most by various multidisciplinary rehabilitation programs?
  d. What kinds of harms are experienced by patients participating in various multidisciplinary rehabilitation programs?
2. Subgroups: Does the efficacy of specific multidisciplinary rehabilitation programs vary across patient subgroups?
3. Timing: At what stage of recovery do multidisciplinary rehabilitation programs offer the best chance of improvement to patients?
4. Intervention Characteristics: Which [underlined: intervention characteristics] predict response in various forms of multidisciplinary rehabilitation programs?
5. Multidisciplinary rehabilitation program versus accessible rehabilitation: What is the comparative effectiveness of various types of multidisciplinary rehabilitation programs versus rehabilitation typically covered by third party payers?
6. Sustainability: Are benefits received from multidisciplinary rehabilitation programs sustained over the long-term?
7. Followup: What level and type of followup care allows for maintenance or prevents deterioration of rehabilitation gains at given time periods post rehabilitation?