# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
EPC: Evidence-based Practice Center
FRN: Future Research Needs
KQ: Key Question
MCID: Minimum clinically important difference
PICOTS: Population, intervention, comparison, outcome, timing, and setting
RCT: Randomized controlled trial
TBI: Traumatic brain injury