# Results

## Research Needs

### Prioritization Results

Stakeholders separately prioritized three groups of questions (methodological, episodic migraine, and chronic migraine). Of the 10 stakeholders invited to participate in the prioritization process, six prioritized methodological research questions, seven prioritized episodic migraine topical research questions, and six prioritized chronic migraine topical research questions. We analyzed cumulative prioritizations (total number of stars assigned to each question) for each group of research questions to identify natural breakpoints (Tables 2–4). High-priority research questions were deemed research needs.

Table 2 Stakeholder prioritization of methodological research questions

Tier | Research Question Cumulative Ranking (n=6) | Total Stars | Number Stakeholders Prioritizing
Tier 1: High Priority | How should research of pharmacologic treatment for chronic migraine define treatment success? | 4 | 3
Tier 1: High Priority | How should chronic migraine populations be defined in trials? | 4 | 2
Tier 1: High Priority | What biomarkers help predict treatment response? | 4 | 2
Tier 2: Moderate Priority | How should research of pharmacologic treatments for episodic migraine define treatment success? | 3 | 3
Tier 2: Moderate Priority | How should adverse effects be measured and reported in pharmacologic studies for the prevention of chronic and/or episodic migraine? | 3 | 2
Tier 2: Moderate Priority | Should episodic and chronic migraine be treated as one progressive disease or as conditions arising from separate physiological mechanisms? | 3 | 2
Tier 2: Low Priority | What is the appropriate timing to evaluate treatment success or failure for each drug/class of drug for preventing chronic and/or episodic migraine? | 2 | 2
Tier 4: Not Prioritized by Stakeholders | What is the minimal clinically important difference for the Migraine Disability Assessment questionnaire scores? | 0 | 0

Table 3 Stakeholder prioritization of episodic migraine research questions

Tier | Research Question (PICOTS element) Cumulative Ranking (n=7) | Total Stars | Number Prioritizing
Tier 1: High Priority | What is the optimal duration of preventive pharmacologic treatments for episodic migraine? (T) | 5 | 4
Tier 1: High Priority | If preventive drug treatment for episodic migraine is effective but discontinued, how likely is it that the episodic migraine will return to previous levels? (I, O) | 5 | 4
Tier 1: High Priority | What is the efficacy of pharmacologic treatments with respect to patient quality of life, migraine-related disability, and health care utilization in preventing episodic migraine? (O) | 4 | 3
Tier 1: High Priority | What is the efficacy of multimodal treatments (pharmacologic, behavioral, etc.) in preventing episodic migraine? (I) | 4 | 4
Tier 1: High Priority | Are combinations of pharmacologic treatments effective in preventing episodic migraine in patients for whom treatment with a single preventive drug has been either ineffective or intolerable? (I) | 4 | 3
Tier 1: High Priority | Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for episodic migraine? (P) | 4 | 4
Tier 2: Moderate Priority | What is the long-term (>1 year) effectiveness of preventive pharmacologic treatments for episodic migraine? (O) | 3 | 2
Tier 2: Moderate Priority | What is the efficacy of angiotensin acting drugs (ACE inhibitors, angiotensin receptor blockers) in preventing episodic migraine? | 2 | 1
Tier 2: Moderate Priority | What is the efficacy of preventive pharmacologic treatments for episodic migraine combined with treatment of existing comorbidities? (P, I) | 2 | 2
Tier 2: Moderate Priority | What is the comparative effectiveness (head-to-head trials) of angiotensin acting drugs, beta blockers, [antidepressants], and antiepileptics in preventing episodic migraine? (I, C) | 2 | 2
Tier 2: Moderate Priority | What is the comparative effectiveness (head-to-head trials) of preventive pharmacologic treatments for episodic migraine in terms of validated measures of quality of life and migraine-related disability? (O) | 2 | 1
Tier 2: Moderate Priority | What is the comparative effectiveness (head-to-head trials) of preventive pharmacologic treatments for episodic migraine with regard to health care utilization (emergency department visits, hospitalizations, acute drug utilization, mental health visits, and medication overuse)? (O) | 2 | 2
Tier 2: Moderate Priority | What is the mechanism of action for drugs from each pharmacologic class used for episodic migraine prevention? (I) | 2 | 1
Tier 2: Moderate Priority | What is the long-term (>1 year) safety of preventive pharmacologic treatments for episodic migraine? (O) | 2 | 1
Tier 3: Low Priority | What is the dose-response relationship with regard to migraine occurrence and severity from preventive pharmacologic treatments for episodic migraine? (I, O) | 1 | 1
Tier 3: Low Priority | What are the comparative harms (head-to-head trials) of angiotensin acting drugs, beta blockers, [antidepressants], and antiepileptics for preventing episodic migraine? (I, C) | 1 | 1
Tier 3: Low Priority | What is the dose response relationship with regard to harms from preventive pharmacologic treatments for episodic migraine? (I, O) | 1 | 1
Tier 3: Low Priority | What is the efficacy of preventive pharmacologic treatments in preventing episodic migraine in patient subgroups? (P) | 1 | 1
Tier 3: Low Priority | What is the comparative effectiveness (head-to-head trials) between angiotensin acting drugs, beta blockers, and approved antiepileptics for preventing episodic migraine in patient subgroups? (P) | 1 | 1
Tier 3: Low Priority | What are the comparative harms (head-to-head trials) of angiotensin acting drugs, beta blockers, antidepressants, and approved antiepileptics for preventing episodic migraine in patient subgroups? (P) | 1 | 1
Tier 4: Not Prioritized by Stakeholders | How does patient compliance with pharmacologic treatment for episodic migraine affect efficacy? (P) | 0 | 0

PICOTS = Population, intervention, comparison, outcome, timing, and setting

Table 4 Stakeholder prioritization of chronic migraine research questions

Tier | Research Question Cumulative Ranking (n=7) | Total Stars | Number Prioritizing
Tier 1: High Priority | Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for chronic migraine? (P) | 7 | 4
Tier 1: High Priority | What is the long-term (>1 year) effectiveness of preventive pharmacologic treatments for chronic migraine? (O) | 6 | 5
Tier 1: High Priority | What is the optimal duration of preventive pharmacologic treatments for chronic migraine? (T) | 5 | 4
Tier 2: Moderate Priority | Are combinations of pharmacologic treatments effective in preventing chronic migraine in patients for whom treatment with a single preventive drug has been either ineffective or intolerable?(I) | 4 | 4
Tier 2: Moderate Priority | If preventive drug treatment for chronic migraine is effective but discontinued, how likely is it that the episodic migraine will return to previous levels? (I, O) | 4 | 4
Tier 2: Moderate Priority | What is the efficacy of pharmacologic treatments with respect to patient quality of life, migraine-related disability, and health care utilization in preventing chronic migraine? (O) | 3 | 3
Tier 2: Moderate Priority | What is the efficacy of multimodal treatments (pharmacologic, behavioral, etc.) in preventing chronic migraine? (I) | 3 | 3
Tier 3: Low Priority | What is the comparative effectiveness (head-to-head trials) of angiotensin acting drugs, beta blockers, [antidepressants], and antiepileptics in preventing chronic migraine? (I, C) | 2 | 2
Tier 3: Low Priority | What is the comparative effectiveness (head-to-head trials) of preventive pharmacologic treatments for chronic migraine with regard to health care utilization (emergency department visits, hospitalizations, acute drug utilization, mental health visits, and medication overuse)?(O) | 2 | 2
Tier 3: Low Priority | What are the comparative harms (head-to-head trials) of angiotensin acting drugs, beta blockers, antidepressants, and approved antiepileptics for preventing chronic migraine in patient subgroups? (P) | 2 | 2
Tier 3: Low Priority | What is the efficacy of preventive pharmacologic treatments in preventing chronic migraine in patient subgroups? (P) | 2 | 2
Tier 3: Low Priority | What is the efficacy of preventive pharmacologic treatments for chronic migraine combined with treatment of existing comorbidities? (P, I) | 1 | 1
Tier 3: Low Priority | What is the dose-response relationship with regard to migraine occurrence and severity from preventive pharmacologic treatments for chronic migraine? (I, O) | 1 | 1
Tier 4: Not Prioritized by Stakeholders | What is the efficacy of angiotensin acting drugs (ACE inhibitors, angiotensin receptor blockers) in preventing chronic migraine? | 0 | 0
Tier 4: Not Prioritized by Stakeholders | How does patient compliance with pharmacologic treatment for chronic migraine affect efficacy? (P) | 0 | 0
Tier 4: Not Prioritized by Stakeholders | What is the comparative effectiveness (head-to-head trials) of preventive pharmacologic treatments for chronic migraine in terms of validated measures of quality of life and migraine-related disability? (O) | 0 | 0
Tier 4: Not Prioritized by Stakeholders | What is the mechanism of action for drugs from each pharmacologic class used for chronic migraine prevention? (I)
Tier 4: Not Prioritized by Stakeholders | What is the dose-response relationship with regard to harms from preventive pharmacologic treatments for chronic migraine? (I, O)
Tier 4: Not Prioritized by Stakeholders | What is the long-term (>1 year) safety of preventive pharmacologic treatments for chronic migraine? (O) | 0 | 0
Tier 4: Not Prioritized by Stakeholders | What is the comparative effectiveness (head-to-head trials) of angiotensin acting drugs, beta blockers, and approved antiepileptics for preventing chronic migraine [underlined: in] patient subgroups? (P) | 0 | 0
Tier 4: Not Prioritized by Stakeholders | What are the comparative harms (head-to-head trials) of angiotensin acting drugs, beta blockers, and approved antiepileptics for preventing chronic migraine in patient subgroups? (P) | 0 | 0

PICOTS=Population, intervention, comparison, outcome, timing, and setting

### Ongoing Studies

We conducted a search for ongoing studies in ClinicalTrials.gov (search strategy appears in Appendix B). Our search identified 163 studies. Thirty-two of these studies (Appendix C) were either completed but not yet published or ongoing and relevant to the scope of the CER. These studies will provide valuable information; however, it is unclear whether the recently completed or currently ongoing studies will sufficiently address identified future research questions. Therefore, our research questions were not revised based upon these ongoing studies. We discuss those relevant to identified research needs.

## Methodological Research Needs

Three of the eight methodological research questions received five or more stars and were thus the top three research questions according to our stakeholders. We designated these as our methodological research needs:

- How should research of pharmacologic treatment for chronic migraine define treatment success?
- How should chronic migraine populations be defined in trials?
- What biomarkers help predict treatment response?

Addressing these methodological research needs will enhance the utility and translation of current and future research on pharmacologic treatments for the prevention of episodic or chronic migraine in adults. Methodological issues surrounding the study of chronic migraine were of upmost importance to stakeholders. This is likely due to the fact that the classification of chronic migraine by the International Headache Society (IHS) is relatively recent43 (although recognition and definition of the condition, then termed “transformed migraine,” began in the 1980s).

Additionally, classifications thus far have proved controversial. Chronic migraine was first classified by the IHS in ICHD-2 in 2004. This definition (1) was much stricter than had been described in previous literature; (2) did not correlate well with populations fitting the transformed migraine definition; and (3) was complicated in practice. Thus, it was revised in 2006.^26^ The 2006 revision was considerably broader, but nonetheless proved problematic in terms of defining chronic migraine populations in trials, clinical practice, and epidemiological studies. Lack of a consistent definition remains an obstacle to interpretation and synthesis of chronic migraine research.43 This in part explains our stakeholders’ major concern about reaching a consensus definition for chronic migraine populations. Whether consensus can be achieved prior to publication of the upcoming ICHD-3, expected in 2013,^44^ remains to be seen.

Operationalizing treatment success of preventive pharmacologic treatments for chronic migraine was identified as a research need despite current related consensus work. The NINDS Headache Common Data Element (CDE) Project recently released recommendations from the Headache Preventive Therapies Subgroup for measuring outcomes in headache trials.39 These recommendations were not specific to chronic migraine, and the population of chronic migraine patients is a small proportion of those with headache. Therefore stakeholders may have believed that specific discussion should address outcomes for chronic migraine patients.

The third methodological research need addresses particular biomarkers that may be associated with treatment response. Identifying biomarkers in migraine received important recognition in a special issue of “Headache” in 2006.^45^ Our stakeholders provided an indication that despite research on biomarkers since that special issue, important questions remain, especially with regard to how biomarkers could potentially help patients and clinicians make informed choices about preventive treatments.

### Considerations for Potential Research

These methodological research needs could be addressed through consensus development, additional systematic reviews, post hoc analyses of previous trial data, and/or qualitative research. One way to identify outcomes specifically valued by chronic migraine patients may involve beginning where the CDE Headache Preventive Therapies group left off.39 The knowledge of this workgroup gained while selecting measures for headache in general likely offers direction to identifying potential measures specific to migraine.

Reviewing the literature for reports of patient opinions or preferences may also provide background. Qualitative research might also contribute. For example, by using focus groups with patients with chronic migraine and their families, employers would help to identify patient-centered outcomes. Preferred outcomes are likely associated with current condition severity and treatment burden.

Arriving at a consensus definition of chronic migraine that is easily implemented in trials and translates well to clinical practice has been shown to be a challenging task. However, continued consultations among researchers and providers along with continued field testing of various definitions46 should ultimately produce a definition that is meaningful, feasible, and useful for research and practice.

Identifying biomarkers that can be reliably used to assist in predictions of preventive pharmacologic treatment response would greatly assist decision makers. While research continues to identify these markers, synthesizing the current state of knowledge on this topic could help to identify specific directions to next approach. Knowledge could also be gained through post hoc analysis of previous trial data to explore potential relationships.

## Topical Research Needs

Natural breakpoints in weighted rankings revealed six prominent topical research needs relevant to episodic migraine and three relevant to chronic migraine. Topical research needs addressed a range of PICOTS elements including the population, intervention, outcome, and timing. Stakeholders did not prioritize basic efficacy questions that have been studied in numerous trials. Nor did they prioritize questions about the comparative effectiveness of different treatments. They were most interested in identifying specific details about these efficacious treatments that can better inform practice decisions and communication with patients. Although most of these research needs were directly addressed by the CER, two research needs were tangential to the CER KQs. Those addressed by the CER remain research needs because the evidence on these specific questions was insufficient or lacked strength.

### Episodic Migraine: First Topical Research Need

- What is the optimal duration of preventive pharmacologic treatments for episodic migraine?

The CER addressed this research need with a question examining the influence of dose and duration of treatment on patient-centered outcomes (KQ 1e). The studies identified for this KQ examined different doses of the drugs and measured outcomes at 2 to 3 months of followup. The short timeframes analyzed in trials along with some guidance suggesting that successful preventive drugs be taken for “3 to 6 months” or for “several months”47 seem to contradict the nature of the condition and the length of treatment that occurs in practice. Limited research exists regarding migraine frequency after discontinuation of preventive treatment.3 The CER did not find good evidence for long-term effectiveness and safety with preventive drugs.

The recent guideline report from the Canadian Headache Society addressed the question of how long to continue preventive treatment, concluding that little evidence is available to inform these decisions. They recommended that tapering and discontinuing preventive medications be considered after 6 to 12 months of successful treatment.47 Stakeholders agreed that the ideal time to treat patients with preventive pharmacologic treatments it is not well understood. Future studies testing these longer timeframes for discontinuing preventive pharmacologic treatment would inform clinical practice.

#### Research Design Considerations

Studies of the efficacy or comparative effectiveness of preventive pharmacologic treatments for migraine need to use experimental designs to achieve valid results. These studies will likely test a hypothesis that longer durations of preventive treatment are more effective than shorter durations. Therefore, studies should include groups of patients with variation in treatment duration in order to test the hypothesis my identifying differences in outcomes between groups. These treatment-related research questions are most appropriately studied with adequately powered double-blind randomized controlled trials. Double blinding is critical for several reasons. First, the nature of the condition relies on patient report and provider judgment for diagnosis and therefore inclusion in intervention studies, as opposed to conditions that use definitive lab values for diagnosis. Second, outcomes used to measure effectiveness are also subjective and self-reported. The large placebo response observed in studies on this topic creates another strong indication that blinding is essential to the validity of studies on this topic.

In addition to blinding, an RCT designed to identify the optimal duration of preventive pharmacologic treatment should pay particular attention to subgroups. Optimal duration of treatment likely varies according to certain patient and migraine characteristics. Therefore, these subgroups need to be identified when the RCT is planned and power calculations should be conducted to insure adequate subgroup sample sizes. Detailed study design considerations regarding the conduct of RCTs to address this research need are described in Table 5.

Table 5 Episodic migraine: design considerations for first topical research need

Research Question: What is the optimal duration of preventive pharmacologic treatments for episodic migraine?
Considerations | RCT
Design Description | Individual patients randomly assigned to preventive pharmacologic treatments of varying duration.
Population | Adults with episodic migraine.
Intervention | Active preventive pharmacologic treatment (i.e. tricyclic antidepressant) for 6, 9, or 12 months followed by placebo.
Comparator | Preventive pharmacologic treatment (i.e. tricyclic antidepressant) for 3 months followed by placebo.
Outcomes | Migraine frequency, quality of life, patient satisfaction, lost work days
Timing | Outcomes measurement should extend through at least one-year from cessation of pharmacologic treatment; longer follow-up would be clinically valuable.
Setting | Headache clinic
Advantages for Producing a Valid Result | This design is likely to produce the most valid results. Blinding is necessary to insure validity. Analysis of specific subgroups identified a priori would enhance the clinical usefulness and generalizability.
Resource use, size and duration | Necessary to recruit large samples and follow for significant length of time; power calculation with planned subgroup analysis should be conducted to determine appropriate sample size.
Ethical, legal, and social issues | Ethical challenges are expected to be minimal. Harms related to longterm use of preventive pharmacologic treatments for migraine unclear; however most drugs used long term for other conditions.
Availability of data/ability to recruit | Fair. Condition is fairly prevalent and preventive pharmacologic treatments are standard care with harms that are not typically life-threatening. Intervention requires significant time commitment from patients, but no other significant recruitment problems are expected.

### Episodic Migraine: Second Topical Research Need

- If preventive pharmacologic treatment for episodic migraine is effective but discontinued, how likely is it that the episodic migraine will return to previous levels?

This research need was not specifically addressed within the KQs of the CER, but relates to treatment duration addressed in KQ 1e and the previous research need (Episodic Migraine: First Topical Research Need). A recent review discusses the few studies that have evaluated discontinuation after successful short courses of preventive drugs (topiramate, valproate, and flunarizine) and reports that relapse does occur in most patients.47 Stakeholders agreed that an improved understanding of the consequences of discontinuing treatment was needed.

#### Research Design Considerations

This question could be considered a subquestion in an RCT addressing the first research need regarding optimal duration of treatment. However, a more clinically meaningful population in which to analyze outcomes after discontinuing treatment would be those treated successfully with a preventive pharmacologic treatment for which treatment was discontinued treatment based on some objective clinical measure, as opposed to time frame alone.

An observational study design could be used to evaluate the effects of discontinuing preventive pharmacologic treatment in this population. Patients achieving success with treatment and ready to discontinue treatment could be recruited and followed over time, and their headache frequency could be assessed at multiple intervals. Table 6 describes research design considerations relevant to this research need. As with the previous research need, subgroups based upon patient or disease characteristics (i.e., length of time with episodic migraine, comorbidities) are likely important correlates of post treatment headache treatment and studies designed to test specific subgroups of patients will be most valuable.

Table 6 Episodic migraine: design considerations for second topical research need

Research Question: If preventive drug treatment for episodic migraine is effective but discontinued, how likely is it that the episodic migraine will return to previous levels?
Considerations | Interrupted Time Series (Without a Comparison Group)
Design Description | A cohort of individuals successfully completing a course of preventive pharmacologic treatment selected and followed over time to determine if episodic migraine returns to previous levels.
Population | Individuals successfully treated for episodic migraine and discontinuing preventive pharmacologic treatment.
Intervention | Migraine frequency at specified intervals after discontinuing treatment
Comparator | Migraine frequency during active treatment
Outcomes | Migraine frequency, quality of life, patient satisfaction, lost work days
Timing | Individuals followed for several months to years.
Setting | Headache clinic
Advantages for Producing a Valid Result | Because there is no intervention and therefore no concerns about selection bias, results should be valid. However, results are likely related to specific patient and disease characteristics so a large sample capable of testing subgroup differences is necessary to provide the most clinically valuable information. It will be necessary to perform power calculations to determine sufficient sample size within each a priori identified subgroup. Important to have baseline data on headache frequency prior to pharmacologic treatment for comparison purposes. Implications about whether and how the large placebo effect observed in efficacy trials for preventive pharmacologic treatments might influence results should be considered. Results may only be generalizable only to population that discontinues treatment as defined in study.
Resource use, size and duration | Resource requirements are high because a large sample size and long-term followup are necessary to provide clinically useful information.
Ethical, legal, and social issues | Minimal.
Availability of data/ability to recruit | Recruitment/data should be fairly easy to obtain. Efforts to maintain the sample over course of study will be necessary.

### Episodic Migraine: Third Topical Research Need

- What is the efficacy of pharmacologic treatments with respect to patient quality of life, migraine-related disability, and health care utilization in preventing episodic migraine?

CER investigators identified several RCTs that examined quality of life, however judged that the evidence lacked the strength necessary for robust conclusions and merited future research. Specifically, few studies assessed the clinical importance of the changes in quality of life or disability scales. The CER does discuss results from several trials that analyzed quality of life types of outcomes (as measured with a variety of scales) and suggests that preventive treatment typically improved quality of life (topiramate, divalproex). While use of acute medications is a commonly used outcome in episodic migraine trials, other health care use outcomes such as emergency department visits were not often included.

Our stakeholders agreed that the currently available evidence does not adequately measure the true burden of preventative pharmacologic treatments for episodic migraine. For instance, a treatment that decreases headache frequency by 50 percent may not be perceived as an improvement if patients become so fatigued or nauseous that they are still unable participate in social roles and activities. Therefore, additional efficacy trials with outcomes measured using validated quality of life measures would provide a clearer indication of the true benefit of preventive medications. Future research is needed to address efficacy, comparative effectiveness, and safety in terms of the net impact on patients’ lives.

#### Research Design Considerations

As we previously mentioned, migraine prevention efficacy is best studied with appropriately powered double-blind randomized controlled trials. Trials to address this research need will be similar to trials that have been previously conducted, but using additional patient-centered outcomes. Table 7 describes specific considerations for designing trials to assess these outcomes.

Table 7 Episodic migraine: design considerations for third topical research need

Research Question: What is the efficacy of preventive pharmacologic treatments with respect to patient quality of life, migraine-related disability, and health care utilization in preventing episodic migraine?
Considerations | RCT
Design Description | Individual patients randomly assigned to preventive pharmacologic treatments and follow over time.
Population | Adults with episodic migraine.
Intervention | Preventive pharmacologic treatments.
Comparator | Placebo.
Outcomes | Quality of life, migraine-related disability, health care utilization.
Timing | Followup should extend through duration of treatment.
Setting | Headache clinic.
Advantages for Producing a Valid Result | This design is necessary to produce valid results. However, measurement of subjective outcomes and interpretation of changes in scale scores presents limitations. Blinding is necessary to insure validity.
Resource use, size and duration | High; large sample sizes to test differences among subgroups would provide most clinically meaningful information.
Ethical, legal, and social issues | Ethical challenges exist. Randomization to placebo may be considered inadequate care. Harms related to intervention not typically life threatening.
Availability of data/ability to recruit | Moderate. Intervention requires time commitment from participants; participants may be unwilling to be randomized to placebo.

### Episodic Migraine: Fourth Topical Research Need

- What is the efficacy of multimodal treatments (pharmacologic, behavioral, etc.) in preventing episodic migraine?

Current clinical practice for migraine prevention often involves multimodal treatments (a combination of pharmacologic, psychological, lifestyle, cognitive, and other interventions). How well these combined treatments work, the marginal benefits above pharmacologic treatments alone, and in which patients they offer a greater benefit over pharmacologic treatments alone needs improved understanding. The four studies evaluating multimodal treatments analyzed in the CER suggested that these programs may offer benefits beyond preventive pharmacologic treatments alone. Stakeholders suggested the need for additional research to address these programs be conducted with precise intervention definitions or protocols, and assessments of how they work and with which patients.

#### Research Design Considerations

RCTs that assess the efficacy of these combined interventions would add value to the current body of evidence. Studies addressing this research need will test the hypothesis that multimodal treatments are superior to preventive pharmacologic treatments. The most important multimodal treatments to test are those commonly used in practice and are likely to include a preventive medication along with some type of behavioral therapy as compared with medication as the only preventive treatment. Therefore, the most important trials to address this research need are large comparative effectiveness trials with a diverse set of participants and sample sizes of subgroups of patients sufficient to test subgroup effects. Specific research design considerations for these trials are described in Table 8.

Table 8 Episodic migraine: design considerations for fourth topical research need

Research Question: What is the efficacy of multimodal treatments (pharmacologic, behavioral, etc.) in preventing episodic migraine?
Considerations | RCT
Design Description | Individual patients randomly assigned to either multimodal treatments (combination of pharmacologic, behavioral, etc. treatments) or a single mode of treatment (e.g., pharmacologic only) and follow them over time to measure efficacy in preventing episodic migraine.
Population | Adults with episodic migraine.
Intervention | Multimodal treatments typically used in practice (combination of pharmacologic, behavioral, etc. treatments).
Comparator | Single mode of preventive treatment (pharmacologic only).
Outcomes | Migraine frequency, quality of life, patient satisfaction, lost work days.
Timing | Studies of treatment duration of at least 6 months will provide the most clinically useful information.
Setting | Headache clinic.
Advantages for Producing a Valid Result | This design is necessary to produce the valid results. Blinding is necessary to insure validity. Generalizability may be low.
Resource use, size and duration | High; large sample sizes to test differences among subgroups would provide most clinically meaningful information; likely necessary to recruit large samples and follow for significant length of time.
Ethical, legal, and social issues | Ethical challenges exist. However, both arms involve standard treatment that is not invasive and harms are not typically life threatening.
Availability of data/ability to recruit | Fair, condition has fairly high prevalence.

### Episodic Migraine: Fifth Topical Research Need

- Are combinations of pharmacologic treatments effective in preventing episodic migraine in patients for whom treatment with a single preventive drug has been either ineffective or intolerable? (I)

This research need addresses combinations of preventive medications, while the previous question addressed combinations of different types of treatments. Combinations of preventive pharmacologic treatments are used for episodic migraine in some circumstances. The CER does not draw conclusions about the efficacy or comparative effectiveness of drug combinations across classes for prevention of episodic migraine. However, combinations are often used in practice especially in patients with refractory migraine (failed treatment with one drug alone).47 Patients that cannot tolerate certain drugs at necessary dosage might better tolerate combination of drugs at lower doses. While evidence about combination preventive medication treatment is not available from blinded RCTs, several open label trials suggest that preventive drug combinations may be effective when treatment with a single drug has failed.47 Stakeholders are interested in an improved evidence base regarding polypharmacy for migraine prevention (i.e., what is the benefit of adding a second drug when patients are not effectively treated with one drug? Are drug side effects lessened when two drugs are used at lower dosages instead of one drug at a higher dose?).

#### Research Design Considerations

RCTs that compare the effectiveness of multi-drug combinations to single drug treatment are necessary to address this research need. The most important drug combinations to test are those commonly used in practice or those suggested in previously conducted open-label trials. The target population for such trials would be individuals who have failed treatment trials with several preventive medications. Again, blinding and sample size are key considerations. As with most of these research needs, subgroups will likely be a very important predictor of response and key subgroups relevant to this research question should be identified. Once identified, power calculations should be conducted to determine the necessary sample size to test differences between subgroups. Because subgroup analysis may be important and we are comparing two active treatments which may have a small marginal difference, the sample size necessary to address this research need will be large and therefore, resource requirements high. Table 9 provides specific details for consideration in funding and developing studies to address this research need.

Table 9 Episodic migraine: design considerations for fifth topical research need

Research Question: Are combinations of pharmacologic treatments effective in preventing episodic migraine in patients for whom treatment with a single preventive drug has been either ineffective or intolerable?
Considerations | RCT
Design Description | Individual patients randomly assigned to either combination preventive pharmacologic treatment or preventive pharmacologic treatment with a single drug and follow them over time to measure efficacy in preventing episodic migraine.
Population | Adults with episodic migraine that have previously failed preventive pharmacologic treatments with drugs from separate classes when used individually.
Intervention | Combination preventive pharmacologic treatment (e.g., tricyclic antidepressant + beta blocker).
Comparator | Preventive pharmacologic treatment with a single drug/placebo combination.
Outcomes | Migraine frequency, quality of life, patient satisfaction, lost work days.
Timing | Studies of treatment duration of at least 6 months will provide the most clinically useful information.
Setting | Headache clinic.
Advantages for Producing a Valid Result | This design is necessary to produce the valid results. Blinding is necessary to insure validity. Generalizability may be low.
Resource use, size and duration | High; large sample sizes to test differences among subgroups would provide most clinically meaningful information; likely necessary to recruit large samples and follow for significant length of time.
Ethical, legal, and social issues | Ethical challenges exist. However, both arms involve standard treatment that is non-invasive and harms are not typically life threatening.
Availability of data/ability to recruit | Fair, condition has fairly high prevalence.

### Episodic Migraine: Sixth Topical Research Need

- Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for episodic migraine? (P)

Disease characteristics among adults suffering from episodic migraine can vary widely. Patients may have suffered from episodic migraine for as little as a few months to several years providing a wide range of chronicity. In addition to chronicity, other disease characteristics vary as well. Some individuals may suffer from an average of five headaches per month and others 15. The duration and severity of those headaches can also vary widely from individual to individual. Many of these characteristics are thought to influence patient response to preventive pharmacologic treatment. KQ 3 of the CER addressed the patient characteristics that influenced response to preventive medication. However, data was only available for a few condition-specific categories (e.g., migraine with aura, baseline migraine frequency) for certain medications. The Canadian Headache Society guidelines recommend preventive migraine medications specifically for patients with certain comorbidities (increased body mass index, hypertension, and depression/anxiety).47 Our stakeholders agreed that an improved understanding of how disease characteristics modify treatment effectiveness would aid decisionmaking.

#### Research Design Considerations

While post hoc analyses of previous RCTs or cohort studies could be used to identify potential relationships between specific disease characteristics and response to treatment with particular drugs, a large RCT is the best approach to testing the hypothesized relationship. Most valuable would be to test relationships previously identified, but rated insufficient or low strength evidence, as well as relationships suspected based on observational studies or clinical practice. Power calculations will be critical to determine sample size with adequate subgroup populations necessary to test differences between groups. Specific research design considerations are similar to other research needs and described in Table 10. If RCTs are not feasible, prospective cohort studies could be designed to enable larger samples, but investigators must take adequate steps to adjust for selection bias.

Table 10 Episodic migraine: design considerations for sixth topical research need

Research Question: Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for episodic migraine?
Considerations | RCT
Design Description | Individual patients randomly assigned to preventive pharmacologic treatments or placebo and followed over time.
Population | Adults with episodic migraine. A sample with diverse disease characteristics will be necessary.
Intervention | Preventive pharmacologic treatments.
Comparator | Placebo or active treatment.
Outcomes | Migraine frequency, quality of life, patient satisfaction, lost work days.
Timing | Studies of treatment duration of at least 6 months will provide the most clinically useful information.
Setting | Headache clinic.
Advantages for Producing a Valid Result | This design is necessary to produce the valid results. Blinding is necessary to insure validity. A large sample capable of testing these characteristics via subgroup differences is necessary. It will be necessary to perform power calculations to determine sufficient sample size within each a priori identified subgroup necessary to test differences. Overall sample size can then be approximated based upon distribution of disease characteristics in population. Generalizability will be enhanced by the recruitment of a diverse sample, but will be lower than cohort studies.
Resource use, size and duration | High; large sample sizes to test differences among subgroups is necessary and participants will likely need to be followed for several months.
Ethical, legal, and social issues | Ethical challenges exist. However, both arms involve standard treatment that is noninvasive, and harms are not typically life threatening.
Availability of data/ability to recruit | Fair, condition has fairly high prevalence. May be necessary to recruit patients from several headache clinics to insure adequate sample size within subgroups.

### Chronic Migraine: First Topical Research Need

- Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for chronic migraine? (P)

Fewer research questions rose to the top of the ranking process for chronic migraine prevention. While far fewer individuals suffer from chronic migraine than episodic migraine, the impact of the condition on their lives is substantially greater. Improved knowledge around these treatment-specific research needs could eventually lessen the disease burden among those suffering from chronic migraine.

This research need mirrors one aimed at the episodic migraine population. Enhanced knowledge on disease characteristics and response to treatment appears even more critical with regard to chronic than episodic migraine. However, data examining these relationships is even scarcer with regard to chronic migraine. The CER reported one trial that examined subgroup effects (prior topiramate use and medication overuse) of preventive treatment (topiramate vs. topiramate plus propanolol) in chronic migraine. Many other subgroups need to be analyzed to improve understanding of the influence of specific disease characteristics.

#### Research Design Considerations

Design issues for RCTs regarding preventive pharmacologic treatments for chronic migraine are essentially identical to those of episodic migraine for the corresponding research need, but have greater challenges. Conducting RCTs with chronic migraine populations will be more difficult given the lower prevalence of the condition. Multi-site trials should be considered to recruit adequate sample sizes. Additionally, investigators might expect a greater degree of attrition among chronic migraine participants than among episodic migraine participants due to their poorer health status. Specific research design considerations are described in Table 11.

Table 11 Chronic migraine: design considerations for first topical research need

Research Question: Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for episodic migraine?
Considerations | RCT
Design Description | Individual patients randomly assigned to preventive pharmacologic treatments or placebo and followed over time.
Population | Adults with chronic migraine with diverse disease characteristics.
Intervention | Preventive pharmacologic treatments.
Comparator | Placebo.
Outcomes | Migraine frequency, quality of life, patient satisfaction, lost work days.
Timing | Studies of treatment duration of at least 6 months will provide the most clinically useful information.
Setting | Headache clinic.
Advantages for Producing a Valid Result | This design is necessary to produce the valid results. Blinding is necessary to insure validity. A large sample capable of testing these characteristics via subgroup differences is necessary. It will be necessary to perform power calculations to determine sufficient sample size within each a priori identified subgroup necessary to test differences. Overall sample size can then be approximated based upon distribution of disease characteristics in population. Generalizability will be enhanced by the recruitment of a diverse sample, but will be lower than cohort studies.
Resource use, size and duration | High; large sample sizes to test differences among subgroups is necessary and participants will likely need to be followed for several months.
Ethical, legal, and social issues | Ethical challenges exist. However, both arms involve standard treatment that is non-invasive and harms are not typically life threatening.
Availability of data/ability to recruit | Fair, condition has fairly high prevalence. May be necessary to recruit patients from several headache clinics to insure adequate sample size within subgroups.

### Chronic Migraine: Second Topical Research Need

- What is the long-term (> 1 year) effectiveness of preventive pharmacologic treatments for chronic migraine? (O)

While this research question was not highly prioritized for episodic migraine, it is much more relevant for chronic migraine because these individuals often need preventive medications for long periods of time. This specific question was not addressed by the CER; however included trials had timelines much shorter than 1 year. If chronic migraine patients are expected to take preventive medications for years, we need an improved understanding of the long-term effectiveness and harms of these medications.

#### Research Design Considerations

For several reasons, an RCT is not likely feasible for this research need. Therefore, an alternative approach is to select a sample of adults maintaining the same preventive pharmacologic treatment for over one year and evaluate headache frequency and other outcomes at set intervals throughout their treatment. This design, interrupted time series (without a comparison group) is useful to identify trends in outcomes measures during a long course of treatment. Disadvantages include the limitations in the data available, as much of it will be obtained through the patient record and the potential inconsistencies in data collected over time and between providers. Table 12 provides more specific research design considerations for this research need.

Table 12 Chronic migraine: design considerations for second topical research need

Research Question: What is the long-term (> 1 year) effectiveness of preventive pharmacologic treatments for chronic migraine?
Considerations | Interrupted Time Series (Without a Comparison Group)
Design Description | A group of individuals that have maintained a course of treatment for one year or more are selected. Outcomes at 1-year treatment duration are compared with outcomes achieved at other points in course of treatment.
Population | Adults with chronic migraine maintaining preventive treatment regimen for 1 year.
Intervention | Preventive pharmacologic treatment of 1-year duration.
Comparator | Preventive pharmacologic treatment of 3-, 6- and/or 9-months duration.
Outcomes | Migraine frequency, quality of life, patient satisfaction, lost work days.
Timing | Short given that most data is historical.
Setting | Headache clinic data.
Advantages for Producing a Valid Result | Allows for study of unique intervention for rare condition and analysis of trends over time. Outcomes data at different time periods needs to be available in patient record. Results valid only for populations maintaining long-term treatment regimens. Analysis can generate hypothesis to be tested with experimental design.
Resource use, size and duration | Low, data from several headache clinics may be necessary to achieve adequate sample. Large sample that allows subgroup analysis would provide most useful information.
Ethical, legal, and social issues | Minimal, observational study.
Availability of data/ability to recruit | Rare condition and treatment may require coordination from several headache centers.

### Chronic Migraine: Third Topical Research Need

- What is the optimal duration of preventive pharmacologic treatments for chronic migraine? (T)

As with episodic migraine, the optimal duration of preventive pharmacologic treatment is now well understood. Improved understanding should result in improved prescribing behavior. As mentioned previously, scientific evidence does not inform decisions about the optimal treatment duration. This question is relevant for chronic as well as episodic migraine populations.

#### Research Design Considerations

RCTs are the best option for addressing this research need for reasons previously discussed. Recruiting and retaining sample populations will be especially challenging due to the duration of the intervention. This should be considered when calculating sample size. Additional research design considerations are described in Table 13.

Table 13 Chronic migraine: design considerations for third topical research need

Research Question: What is the optimal duration of preventive pharmacologic treatments for episodic migraine?
Considerations | RCT
Design Description | Individual patients randomly assigned to preventive pharmacologic treatments of varying duration.
Population | Adults with chronic migraine.
Intervention | Active preventive pharmacologic treatment (e.g. topiramate) for 6, 9, or 12 months followed by placebo.
Comparator | Preventive pharmacologic treatment (e.g. topiramate) for 3 months followed by placebo.
Outcomes | Migraine frequency, quality of life, patient satisfaction, lost work days.
Timing | Outcomes measurement should extend through at least one-year from cessation of pharmacologic treatment; longer follow-up would be clinically valuable.
Setting | Headache clinic.
Advantages for Producing a Valid Result | This design is likely to produce the most valid results. Blinding is necessary to insure validity. Generalizability may be low.
Resource use, size and duration | Necessary to recruit large samples and follow for significant length of time; power calculation with planned subgroup analysis should be conducted to determine appropriate sample size.
Ethical, legal, and social issues | Ethical challenges are expected to be minimal. Harms related to long-term use of preventive pharmacologic treatments for migraine unclear; however most drugs used long term for other conditions.
Availability of data/ability to recruit | Fair. Condition is fairly prevalent and preventive pharmacologic treatments are standard care with harms that are not typically life threatening. Intervention requires significant time commitment from patients.