# Methods

We used a deliberative process to refine, add, and prioritize research questions to arrive at research needs relevant to the evidence gaps identified in the recently completed CER, “Preventive Pharmacologic Treatments for Migraine.”1 Figure 2 illustrates the eight steps used to accomplish these objectives.

Figure 2 Project flow

CER = Comparartive Effectiveness Review; FRN = Future Research Needs; PICOTS = Population, intervention, comparison, outcome, timing, and setting

Figure 2 describes the flow of the project in 8 steps. Step 1 is to identify the evidence gaps from the CER. Step 2 is to form and orient the stakeholder panel. Step 3 is to translate research gaps into researchable questions. Step 4 is to elicit stakeholder feedback on those questions via conference calls and emails. Step 5 is to revise the list of research gap questions based upon the stakeholder feedback. Step 6 involves having the stakeholders prioritize the revised set of research questions, higly prioritized questions are deemed research needs. Step 7 involves the EPC team identifying research design considerations for these research needs. And Step 8 is to develop the FRN report.

## Engagement of Stakeholders

We recruited a diverse stakeholder panel whose members represented various perspectives relevant to the topic. We followed guidance on stakeholder engagement for recruitment and communication.38 We sought to recruit stakeholders who were actively interested in preventive pharmacologic treatments for migraine and who wished to help shape future research priorities. We identified potential stakeholders via several means. We sought recommendations from the CER project team; we invited select Key Informants and Technical Expert Panel members and reviewed recent literature to identify additional experts on the topic.

Research representatives were national experts who were familiar with: (1) evidence-based medicine; (2) the obstacles often associated with conducting well-designed research; and (3) preventive pharmacologic treatments for migraine from the fields of neuorology and pharmacy. We invited participation from the National Institute of Neurological Disorders and Stroke (NINDS), which supports and conducts relevant research. We engaged providers and consumers because the decisional dilemmas faced by these groups are critical to identifying and prioritizing research questions. Many stakeholders were also involved in the CER process as Key Informants, Technical Expert Panel members, or peer reviewers. This made engaging them as stakeholders challenging, because the timing of the FRN project overlapped with finalization of the CER. However, these stakeholders had the advantage of familiarity with the CER.

## Handling Conflicts of Interest

We collected disclosures of conflicts of interests from all stakeholders. Disclosed interests did not bar any stakeholders from participation but allowed the Evidence-based Practice Center (EPC) to evaluate contributions based upon possible conflicts. Stakeholders used a web-based survey to rank research questions during the prioritization exercise, thus researchers and funders were blind to the others’ stated opinions.

## Refinement of Research Questions

We provided stakeholder panel members with a preliminary set of research questions prior to conference calls. During conference calls, we sought stakeholder input to further refine the research questions (i.e., organization and wording of the questions, identification of additional research questions, and elimination of research questions with limited clinical value). To facilitate this input, we provided stakeholders in advance with the draft CER Executive Summary to provide relevant background to the project. We conducted three conference calls with available stakeholders during June 2012. A total of 12 stakeholders participated in the calls. All participants provided input on the calls. We revised the preliminary questions based on these discussions.

We also revised the preliminary questions in light of recent and ongoing work. For instance, the NINDS Common Data Elements project for headache has addressed several of the limitations CER authors found in the current literature concerning poor reporting of patient and disease characteristics.39 We therefore excluded those questions from the ranking process. The revised set of research questions for prioritization appears in Appendix A.

## Prioritization

Our stakeholders were asked to prioritize these research questions according to specified criteria based on the potential impact of future research addressing each question. These criteria have been operationalized into seven components specific to EPC FRN projects. These components, called “Potential Value Criteria,” are as follows:40

- Potential for significant health impact on the current and future health status of people with respect to burden of the disease and health outcomes: mortality, morbidity, and quality of life.
- Potential to reduce important inappropriate (or unexplained) variation in clinical practices known to relate to quality of care. Potential to resolve controversy or dilemmas in what constitutes appropriate health care. Potential to improve decisionmaking for patient or provider, by decreasing uncertainty.
- Potential for significant (nontrivial) economic impact related to the costs of health service: to reduce unnecessary or excessive costs; to reduce high costs due to high volume use; to reduce high costs due to high unit cost or aggregate cost. Costs may impact consumers, patients, health care systems, or payers.
- Potential risk from inaction: Unintended harms from lack of prioritization of proposed research; opportunity cost of inaction.
- Addresses inequities, vulnerable, diverse populations (including issues for patient subgroups); potential to reduce health inequities.
- Potential to allow assessment of ethical, legal, social issues pertaining to the condition.
- Potential for new knowledge (research would not be redundant; question not sufficiently researched, including completed and in-process research; utility of available evidence limited by changes in practice, e.g., disease detection or evolution in technology).

To collect these prioritizations, we developed a web-based survey using prioritization software developed by the Research Triangle Institute-University of North Carolina Evidence-based Practice Center to collect stakeholder prioritization of the research gap questions.41 Ten stakeholders who completed disclosure statements (less than 10 were non-Federal employees) were invited to rank research questions identified via the stakeholder conference calls. These stakeholders were instructed to assign stars to research questions in three groups (methodological research questions, topical research questions addressing episodic migraine, topical research questions addressing chronic migraine).

Stakeholders’ cumulative star count was used to rank the research questions in each group. We identified natural breakpoints in the prioritizations that separated high, moderate, and low-priority research questions. Highly prioritized research questions were considered research needs.

We then evaluated the feasibility criteria for research needs. We framed feasibility in terms of anticipated research designs. For example, factors that affect the feasibility of conducting randomized controlled trials include the sample size needed for the outcome, the size of the available pool of potential subjects, followup duration, willingness to randomize, and applicability issues. In contrast to randomization and applicability, observational studies face feasibility issues related to measuring study variables with different data sources and unobserved variables that create risk of bias.

## Research Design Considerations

We generated research design considerations for identified research needs. For methodological research needs, we provided context and described resources and research design considerations potentially useful to researchers, facilitators, and funders of this type of research. For topical research needs, we highlighted the relevant element(s) of the PICOTS (population, intervention, comparison, outcome, timing, and setting), provided context, described related ongoing research, and discussed potential research designs. Research design considerations were guided by a recent Agency for Healthcare Research and Quality (AHRQ) report describing frameworks for research design considerations for Future Research Needs.42 We did not consult with stakeholders for input on research design considerations.