# Executive Summary

## Background

This Future Research Needs (FRN) project is a followup to the Comparative Effectiveness Review (CER), “Preventive Pharmacologic Treatments for Migraine.”1 The review was motivated by uncertainty around the effectiveness, comparative effectiveness, and safety of pharmacologic treatments for the prevention of episodic or chronic migraine in adults. To identify research needs, this FRN project used a deliberative process to identify evidence gaps, translate gaps into researchable questions, and solicit stakeholder opinion on the importance of research questions. Addressing these research needs should provide information potentially of value to decisionmakers.

The research questions addressed in the CER relied upon an analytic framework from the original CER (Figure A). The framework describes a process experienced by adults with episodic or chronic migraine seeking preventative pharmacologic treatments. Differentiating between chronic or episodic migraine according to their clinical definitions depends on headache frequency, frequency of migraine type headaches, the presence of aura, and the possibility of headaches associated with overusing acute pain medication. However, in practice, these categories are often simplified in studies with episodic indicating fewer than 15 headache days per month and chronic indicating 15 or more headache days per month). The review addressed important Key Questions (KQs) about the efficacy and comparative effectiveness of these treatments (KQ 1); evaluating the safety of these treatments (KQ 2); and the identification of patient characteristics that predict the effectiveness and safety of pharmacologic treatments for preventing migraine attacks in adults (KQ 3).

Figure A Analytic framework

KQ = Key Question; SES = socioeconomic status

Note: KQ 1: What are the efficacy and comparative effectiveness of pharmacologic treatments for preventing migraine attacks in adults? KQ 2: What are the comparative harms from pharmacologic treatments for preventing migraine attacks in adults? KQ 3: Which patient characteristics predict the effectiveness and safety of pharmacologic treatments for preventing migraine attacks in adults?

Figure A presents a conceptual model and the analytical framework for the key questions within the context of the Population, Interventions, Comparators, Outcomes, and Settings. The framework includes eight headers: target Population for question as adults with migraine, pharmacological and nonpharmacological treatments for adults with migraine, intermediate outcomes such as number of headache days, and clinical outcomes such as quality of life, prevention of migraine attacks, reduction in frequency of migraine attack by at least 50% from baseline, patient satisfaction, emergency visits, and loss of working days. In general, the figure illustrates pharmacological or combined modalities versus placebo, regular care, or active control may result in intermediate outcomes and clinical outcomes. Adverse events may occur at any point after treatment is received. Treatment effects may be modified by age, gender, race, aura, prior treatment, comorbidity, family history, and access to care. The figure also gives information about the research questions. Key Question 1: What are the efficacy and comparative effectiveness of pharmacological treatments for preventing migraine attacks in adults? Key Question 2: What are the comparative harms from pharmacological treatments for preventing migraine attacks in adults? Key Question 3: Which characteristics of children predict the effectiveness and safety of pharmacological treatments for preventing migraine attacks in adults?

### Findings of CER

The CER synthesized data from eligible randomized controlled trials (RCTs) for efficacy and comparative effectiveness.1 Data from these RCTs and additional eligible nonrandomized studies was synthesized for harms. Key findings are summarized below.

#### Prevention of Chronic Migraine

##### Efficacy

Only one drug for chronic migraine, onabotulinumtoxinA, was examined in more than one RCT. OnabotulinumtoxinA was better than placebo in reducing monthly migraine attack by 50 percent or more. A single RCT reported that topiramate was better than placebo in achieving a reduction of headache frequency, but not better than placebo in reducing monthly migraine attacks 50 percent or more.

##### Comparative Effectiveness

Five individual RCTs provided low-strength evidence about the comparative effectiveness of onabotulinumtoxinA versus other drugs for chronic migraine prevention. Individual RCTs examined the comparative effectiveness of onabotulinumtoxinA versus topiramate and found no significant differences in likelihood of migraine prevention or improvement in migraine disability assessment. Absolute scores of the Headache Impact Test were significantly better with topiramate than onabotulinumtoxinA; however, need for acute drugs did not differ between the two. A single RCT examined the comparative effectiveness of onabotulinumtoxinA versus divalproex sodium and found no differences between the two drugs for migraine prevention, migraine-related disability, or quality of life. A single RCT reported that propranolol added to topiramate did not effectively prevent chronic migraine in patients for whom topiramate monotherapy had failed.

##### Safety

OnabotulinumtoxinA resulted in adverse effects and treatment discontinuation due to adverse effects more often than placebo. Increase in risk of adverse effects was dose responsive.

Individual RCTs demonstrated less frequent treatment discontinuation due to adverse effects with onabotulinumtoxinA than topiramate or amitriptyline.

#### Prevention of Episodic Migraine

##### Efficacy

All approved drugs (propranolol, timolol, topiramate, and divalproex sodium) were better than placebo in reducing monthly migraine frequency by 50 percent or more in individual patients. Rates of clinical response were moderate, 200 to 400 patients per 1,000 treated. In addition to ≥50 percent reduction in monthly migraine frequency, individual RCTs of approved antiepileptic drugs and beta blockers improved other patient-centered outcomes. Topiramate demonstrated significant improvements for general health status, quality of life, and disability, with score improvements on the Medical Outcome Study Short Form 36 (SF-36) of more than 200 percent for self-reported vitality and more than 100 percent for improvement in pain and general health. Divalproex in a larger dose of 1,500 mg/day increased the likelihood of a 50 percent improvement in whether migraine attacks impaired usual activities or necessitated symptomatic medication and in reducing migraine attacks with nausea, vomiting, phonophobia, or photophobia. Topiramate and propranolol decreased use of drugs for acute migraine attacks.

Among off-label drugs, pooled analyses demonstrated that antiepileptic gabapentin, beta-blocker metoprolol, and calcium channel blocker nimodipine were better than placebo in reducing monthly migraine attacks by 50 percent or more.

Individual RCTs demonstrated that the off-label anti-epileptics carbamazepin and valproate (but not acetazolamide, lamotrigine, or oxcarbazepine) were better than placebo in reducing monthly migraine attacks by 50 percent or more. Individual RCTs demonstrated that off-label beta blockers acebutolol atenolol and nadolol (but not pindolol or alprenolol) were better than placebo in reducing monthly migraine attacks by 50 percent or more.

Individual RCTs of off-label angiotensin converting enzyme (ACE) inhibiting drugs demonstrated promising results. The ACE inhibitor captopril was examined in a single RCT. When tested in adults with comorbid hypertension and depressive symptoms for whom previous antimigraine drugs had been ineffective, the ACE inhibitor captopril was better than placebo in achieving complete cessation of migraine, improvement in Headache Index scores by 50 percent or more, and reduced depression symptoms. The ACE inhibitor lisinopril was better than placebo in reducing migraine days and migraine severity in patients with episodic migraine with or without hypertension. It reduced pain measured with SF-36, but did not decrease use of drugs for acute migraine attacks.

The off-label angiotensin II antagonist (ARB) candesartan was better than placebo in achieving a clinical response defined as a 50 percent or more reduction in migraine days. Candesartan also decreased migraine-related disability but had no effect on use of drugs for acute migraine attacks. In contrast, ARB telmisartan was not better than placebo in reducing monthly migraine attacks by 50 percent or more.

##### Comparative Effectiveness

Pooled analysis was possible for only four paired drug comparisons for the prevention of episodic migraine, and this analysis demonstrated few significant differences between individual drugs. Exploratory Bayesian network meta-analysis and indirect adjusted analysis of such drugs found no differences among approved drugs. Approved drugs were more effective than off-label drugs except for the angiotensin II receptor blocker candesartan, which was more effective than topiramate, divalproex, and propranolol. Exploratory Bayesian network meta-analysis demonstrated that the approved drugs topiramate, divalproex, and propranolol, and off-label drug classes including angiotensin inhibiting drugs were better than placebo. The strength of the association was the largest with angiotensin inhibiting drugs.

##### Safety

Bothersome adverse effects leading to treatment discontinuation were greater than placebo for topiramate in doses of 100 and 200 mg/day (but not 50 mg/day) and propranolol.

Among off-label drugs, pooled analyses demonstrated that the off-label antidepressant amitriptyline caused bothersome adverse effects leading to treatment discontinuation more often than placebo.

In direct comparisons of divalproex or valproate versus placebo, treatment discontinuation due to adverse effects did not differ. Pooled analysis showed no differences in treatment discontinuation with topiramate versus amitriptyline.

Indirect adjusted analyses demonstrated no differences in treatment discontinuation due to adverse effects with approved drugs or approved versus off-label drugs. Exploratory Bayesian network meta-analyses demonstrated that topiramate and off-label antiepileptics and antidepressants resulted in bothersome adverse effects leading to treatment discontinuation more often than placebo. A network meta-analysis indicated that off-label ACE inhibitors and beta-blockers were the safest treatment option for adults with episodic migraine.

##### Patient Characteristics

Evidence was limited to individual RCTs that examined the drug effect modification by selected patient characteristics:

- Onabotulinumtoxin A was more effective in patients with a higher mean baseline migraine frequency.
- Amitriptyline was better than placebo in reducing monthly migraine but only in patients with depression or with baseline frequent and severe migraine.
- Topiramate was more likely to reduce migraine attacks in women but not in men according to one low-risk-of-bias RCT.
- Several post hoc subgroup analyses of topiramate versus placebo provided inconsistent evidence of the drug efficacy in respect to aura.

### Evidence Gaps

The CER identified gaps and biases in available evidence and made future research recommendations.1 Findings from the CER drew conclusions about the efficacy and comparative effectiveness of the off-label use of ACE inhibitors and ARBs for migraine prevention that were stronger than current guidelines suggest. Because these conclusions were drawn from a small number of RCTs, future research could refute or validate the results of these early studies. Additionally, well-designed randomized clinical trials should examine the comparative effectiveness via head-to-head trials of approved drugs and the most effective off-label ACE inhibitors, ARBs, antidepressants, and beta blockers. Future trials should examine the potential treatment modifying effects of patient age, sex, race, migraine family history, comorbidities, and prior treatment with migraine preventive drugs. The long-term efficacy of most preventive pharmacologic treatments is unknown; evidence on improving quality of life was inconsistent across individual drugs; future research could help clarify these issues. Investigators should strive to better capture adverse effects associated with migraine preventive drugs. Additionally, future research synthesis would benefit from trial registration and posting of results on www.ClinicalTrials.gov.

### Project Purpose

Our FRN project identifies and prioritizes research needs arising from the status of current literature on efficacy, comparative effectiveness, and safety of preventative pharmacologic treatments in adults for the prevention of episodic or chronic migraine. These research needs are presented along with research design considerations and represent the opinion of a select group of stakeholders on issues on which future research has potential value to the current body of evidence.

## Methods

We used a deliberative process to identify and prioritize research questions relevant to the KQs addressed in the CER. Figure B illustrates the eight steps used to accomplish the objectives of this project.

Figure B Project flow

CER = Comparative Effectiveness Review; FRN = Future Research Needs; PICOTS = Population, intervention, comparison, outcome, timing, setting

Figure B describes the flow of the project in 8 steps. Step 1 is to identify the evidence gaps from the CER. Step 2 is to form and orient the stakeholder panel. Step 3 is to translate research gaps into researchable questions. Step 4 is to elicit stakeholder feedback on those questions via conference calls and emails. Step 5 is to revise the list of research gap questions based upon the stakeholder feedback. Step 6 involves having the stakeholders prioritize the revised set of research questions, higly prioritized questions are deemed research needs. Step 7 involves the EPC team identifying research design considerations for these research needs. And Step 8 is to develop the FRN report.

First, we translated the research gaps identified in the CER into research questions. Second, we assembled a diverse stakeholder panel with representation from various perspectives relevant to the topic. Invited research representatives were national experts who were familiar with: (1) evidence-based medicine; (2) the obstacles often associated with conducting well-designed research on migraine prevention; and (3) preventive pharmacologic interventions from the fields of neurology, headache medicine, and pharmacy. We invited participation from representatives from organizations supporting or conducting relevant research, including the representatives from organizations supporting or conducting relevant research including the National Institute of Neurological Disorders and Stroke (NINDS), the National Headache Foundation, and others. Finally, we engaged providers and consumers, because the decisional dilemmas faced by these groups are critical to identifying and prioritizing research questions.

We first held conference calls with stakeholders to refine the draft research questions. Based upon these conversations and an assessment of recent and ongoing work, we revised our initial list of research questions. This revision included separating the questions into categories (methodological research questions that need to be addressed to enhance the usefulness of current research and topical research questions that have not been sufficiently addressed in the current literature, separated further into those addressing episodic migraine and those addressing chronic migraine). We sent this list of research questions to stakeholders for prioritization. Stakeholders assigned a total of seven “stars” (up to three stars for one question) to methodological research questions and a total of seven stars (up to three stars for one question) for topical episodic and chronic research questions from a total of 21.

Cumulative stars across all stakeholders were used to rank order each category of research questions to determine their relative importance. Based upon natural breakpoints in the rankings, we determined high, moderate, and low-priority research questions. High-priority questions were deemed research needs. We then identified and discussed research design considerations for those identified research needs.

## Results

### Prioritization Results

We analyzed stakeholder prioritization results. Of the 10 stakeholders invited to rank research questions, 6 ranked methodological questions, 7 ranked topical questions related to episodic migraine, and 6 ranked topical questions related to chronic migraine.

### Methodological Research Needs

Three of the eight methodological research questions received five or more stars from four to five stakeholders, delineating the top three research questions according to our stakeholders. We designated this top tier our methodological research needs:

- How should research of pharmacologic treatment for [underlined: chronic] migraine define treatment success?
- How should [underlined: chronic] migraine populations be defined in trials?
- What biomarkers help predict treatment response?

### Considerations for Potential Research

These methodological research needs could be addressed through consensus development, additional systematic reviews, post hoc analyses of previous trial data, and/or qualitative research. One way to identify outcomes that are specifically valued by chronic migraine patients may to build on the work of the Common Data Elements (CDE) Headache Preventive Therapies group.2 Although this group focused on selecting measures for headache in general, the knowledge they gained would likely offer direction for identifying measures specific to migraine.

Reviewing the literature for reports of patient opinions or preferences would provide background, and qualitative research might also contribute. For example, by using focus groups with patients with chronic migraine and their families, employers would help to identify patient-centered outcomes. Preferred outcomes are likely associated with current condition severity and treatment burden.

The task of arriving at a consensus definition of chronic migraine that is easily implemented in trials and translates well to clinical practice has proven challenging. However, such a definition should be achievable with continued consultations among researchers and providers along with continued field testing of various definitions.3

Decisionmakers would be greatly assisted by further efforts to synthesize knowledge of biomarkers that can be reliably used to assist in predictions of preventive pharmacologic treatment response. Although research does continue to identify these markers, synthesizing the current knowledge on this topic could help to identify specific directions to next approach. Knowledge could also be gained through post hoc analysis of previous trial data to explore potential relationships between specific biomarkers and patient outcomes.

### Topical Research Needs

Natural breakpoints in weighted rankings revealed six prominent topical research needs relevant to episodic migraine and three relevant to chronic migraine. Topical research needs addressed a range of PICOTS elements including the population, intervention, outcome, and timing. Stakeholders did not prioritize basic efficacy questions that have been studied in numerous trials. Nor did they prioritize questions about the comparative effectiveness of different treatments. They were most interested in identifying specific details about these efficacious treatments that can better inform practice decisions and communication with patients. Although most of these research needs were directly addressed by the CER, two research needs were tangential to the CER KQs. Those addressed by the CER remain research needs because the evidence on these specific questions was insufficient or lacked strength.

#### Episodic Migraine: First Topical Research Need

- What is the optimal duration of preventive pharmacologic treatments for episodic migraine?

The CER addressed this research need with a question examining the influence of dose and duration of treatment on patient-centered outcomes (KQ 1e). The studies identified for this KQ examined different doses of the drugs and measured outcomes at 2 to 3 months of followup. The short timeframes analyzed in trials along with some guidance suggesting that successful preventive drugs be taken for “3 to 6 months” or for “several months”4 seem to contradict the nature of the condition and the length of treatment that occurs in practice. Limited research exists regarding migraine frequency after discontinuation of preventive treatment.5 The CER did not find good evidence for long-term effectiveness and safety with preventive drugs.

The recent guideline report from the Canadian Headache Society addressed the question of how long to continue preventive treatment, concluding that little evidence is available to inform these decisions. They recommended that tapering and discontinuing preventive medications be considered after 6 to 12 months of successful treatment.4 Stakeholders agreed that the ideal time to treat patients with preventive pharmacologic treatments it is not well understood. Future studies testing these longer timeframes for discontinuing preventive pharmacologic treatment would inform clinical practice.

##### Research Design Considerations

Studies of the efficacy or comparative effectiveness of preventive pharmacologic treatments for migraine need to use experimental designs to achieve valid results. These studies will likely test a hypothesis that longer durations of preventive treatment are more effective than shorter durations. Therefore, studies should include groups of patients with variation in treatment duration in order to test the hypothesis my identifying differences in outcomes between groups. These treatment-related research questions are most appropriately studied with adequately powered double-blind randomized controlled trials. Double blinding is critical for several reasons. First, the nature of the condition relies on patient report and provider judgment for diagnosis and therefore inclusion in intervention studies, as opposed to conditions that use definitive lab values for diagnosis. Second, outcomes used to measure effectiveness are also subjective and self-reported. The large placebo response observed in studies on this topic creates another strong indication that blinding is essential to the validity of studies on this topic.

In addition to blinding, an RCT designed to identify the optimal duration of preventive pharmacologic treatment should pay particular attention to subgroups. Optimal duration of treatment likely varies according to certain patient and migraine characteristics. Therefore, these subgroups need to be identified when the RCT is planned and power calculations should be conducted to insure adequate subgroup sample sizes.

#### Episodic Migraine: Second Topical Research Need

- If preventive pharmacologic treatment for episodic migraine is effective but discontinued, how likely is it that the episodic migraine will return to previous levels?

This research need was not specifically addressed within the KQs of the CER, but relates to treatment duration addressed in KQ 1e and the previous research need (Episodic Migraine: First Topical Research Need). A recent review discusses the few studies that have evaluated discontinuation after successful short courses of preventive drugs (topiramate, valproate, and flunarizine) and reports that relapse does occur in most patients.4 Stakeholders agreed that an improved understanding of the consequences of discontinuing treatment was needed.

##### Research Design Considerations

This question might be considered a subquestion to an RCT addressing the first research need regarding optimal duration of treatment. However, a more clinically meaningful population in which to analyze outcomes after discontinuing treatment would be those treated successfully with a preventive pharmacologic treatment for which treatment was discontinued treatment based on some objective clinical measure, as opposed to time frame alone.

An observational study design could be used to evaluate the effects of discontinuing preventive pharmacologic treatment in this population. Patients achieving success with treatment and ready to discontinue treatment could be recruited and followed over time, and their headache frequency could be assessed at multiple intervals. As with the previous research need, subgroups based upon patient or disease characteristics (i.e., length of time with episodic migraine, comorbidities) are likely important correlates of post treatment headache treatment and studies designed to test specific subgroups of patients will be most valuable.

#### Episodic Migraine: Third Topical Research Need

- What is the efficacy of pharmacologic treatments with respect to patient quality of life, migraine-related disability, and health care utilization in preventing episodic migraine?

CER investigators identified several RCTs that examined quality of life, however judged that the evidence lacked the strength necessary for robust conclusions and merited future research. Specifically, few studies assessed the clinical importance of the changes in quality of life or disability scales. The CER does discuss results from several trials that analyzed quality of life types of outcomes (as measured with a variety of scales) and suggests that preventive treatment typically improved quality of life (topiramate, divalproex). While use of acute medications is a commonly used outcome in episodic migraine trials, other health care use outcomes such as emergency department visits were not often included.

Our stakeholders agreed that the currently available evidence does not adequately measure the true burden of preventative pharmacologic treatments for episodic migraine. For instance, a treatment that decreases headache frequency by 50 percent may not be perceived as an improvement if patients become so fatigued or nauseous that they are still unable participate in social roles and activities. Therefore, additional efficacy trials with outcomes measured using validated quality of life measures would provide a clearer indication of the true benefit of preventive medications. Future research is needed to address efficacy, comparative effectiveness, and safety in terms of the net impact on patients’ lives.

##### Research Design Considerations

As we previously mentioned, migraine prevention efficacy is best studied with appropriately powered double-blind randomized controlled trials. Trials to address this research need will be similar to trials that have been previously conducted, but using additional patient-centered outcomes.

#### Episodic Migraine: Fourth Topical Research Need

- What is the efficacy of multimodal treatments (pharmacologic, behavioral, etc.) in preventing episodic migraine?

Current clinical practice for migraine prevention often involves multimodal treatments (a combination of pharmacologic, psychological, lifestyle, cognitive, and other interventions). How well these combined treatments work, the marginal benefits above pharmacologic treatments alone, and in which patients they offer a greater benefit over pharmacologic treatments alone needs improved understanding. The four studies evaluating multimodal treatments analyzed in the CER suggested that these programs may offer benefits beyond preventive pharmacologic treatments alone. Stakeholders suggested the need for additional research to address these programs be conducted with precise intervention definitions or protocols, and assessments of how they work and with which patients.

##### Research Design Considerations

RCTs that assess the efficacy of these combined interventions would add value to the current body of evidence. Studies addressing this research need will test the hypothesis that multimodal treatments are superior to preventive pharmacologic treatments. The most important multimodal treatments to test are those commonly used in practice and are likely to include a preventive medication along with some type of behavioral therapy as compared with medication as the only preventive treatment. Therefore, the most important trials to address this research need are large comparative effectiveness trials with a diverse set of participants and sample sizes of subgroups of patients sufficient to test subgroup effects.

#### Episodic Migraine: Fifth Topical Research Need

- Are combinations of pharmacologic treatments effective in preventing episodic migraine in patients for whom treatment with a single preventive drug has been either ineffective or intolerable? (I)

This research need addresses combinations of preventive medications, while the previous question addressed combinations of different types of treatments. Combinations of preventive pharmacologic treatments are used for episodic migraine in some circumstances. The CER does not draw conclusions about the efficacy or comparative effectiveness of drug combinations across classes for prevention of episodic migraine. However, combinations are often used in practice especially in patients with refractory migraine (failed treatment with one drug alone).4 Patients that cannot tolerate certain drugs at necessary dosage might better tolerate combination of drugs at lower doses. While evidence about combination preventive medication treatment is not available from blinded RCTs, several open label trials suggest that preventive drug combinations may be effective when treatment with a single drug has failed.4 Stakeholders are interested in an improved evidence base regarding polypharmacy for migraine prevention (i.e., what is the benefit of adding a second drug when patients are not effectively treated with one drug? Are drug side effects lessened when two drugs are used at lower dosages instead of one drug at a higher dose?).

##### Research Design Considerations

RCTs that compare the effectiveness of multidrug combinations to single drug treatment are necessary to address this research need. The most important drug combinations to test are those commonly used in practice or those suggested in previously conducted open-label trials. The target population for such trials would be individuals who have failed treatment trials with several preventive medications. Again, blinding and sample size are key considerations. As with most of these research needs, subgroups will likely be a very important predictor of response and key subgroups relevant to this research question should be identified. Once identified, power calculations should be conducted to determine the necessary sample size to test differences between subgroups. Because subgroup analysis may be important and we are comparing two active treatments which may have a small marginal difference, the sample size necessary to address this research need will be large and therefore, resource requirements high.

#### Episodic Migraine: Sixth Topical Research Need

- Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for episodic migraine? (P)

Disease characteristics among adults suffering from episodic migraine can vary widely. Patients may have suffered from episodic migraine for as little as a few months to several years providing a wide range of chronicity. In addition to chronicity, other disease characteristics vary as well. Some individuals may suffer from an average of five headaches per month and others 15. The duration and severity of those headaches can also vary widely from individual to individual. Many of these characteristics are thought to influence patient response to preventive pharmacologic treatment. KQ3 of the CER addressed the patient characteristics that influenced response to preventive medication. However, data was only available for a few condition-specific categories (e.g., migraine with aura, baseline migraine frequency) for certain medications. The Canadian Headache Society guidelines recommend preventive migraine medications specifically for patients with certain comorbidities (increased body mass index, hypertension, and depression/anxiety).4 Our stakeholders agreed that an improved understanding of how disease characteristics modify treatment effectiveness would aid decisionmaking.

##### Research Design Considerations

While post hoc analyses of previous RCTs or cohort studies could be used to identify potential relationships between specific disease characteristics and response to treatment with particular drugs, a large RCT is the best approach to testing the hypothesized relationship. Most valuable would be to test relationships previously identified, but rated insufficient or low strength evidence, as well as relationships suspected based on observational studies or clinical practice. Power calculations will be critical to determine sample size with adequate subgroup populations necessary to test differences between groups. If RCTs are not feasible, prospective cohort studies could be designed to enable larger samples, but investigators must take adequate steps to adjust for selection bias.

#### Chronic Migraine: First Topical Research Need

- Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for chronic migraine? (P)

Fewer research questions rose to the top of the ranking process for chronic migraine prevention. While far fewer individuals suffer from chronic migraine than episodic migraine, the impact of the condition on their lives is substantially greater. Improved knowledge around these treatment-specific research needs could eventually lessen the disease burden among those suffering from chronic migraine.

This research need mirrors one aimed at the episodic migraine population. Enhanced knowledge on disease characteristics and response to treatment appears even more critical with regard to chronic than episodic migraine. However, data examining these relationships is even scarcer with regard to chronic migraine. The CER reported one trial that examined subgroup effects (prior topiramate use and medication overuse) of preventive treatment (topiramate vs. topiramate plus propranolol) in chronic migraine. Many other subgroups need to be analyzed to improve understanding of the influence of specific disease characteristics.

##### Research Design Considerations

Design issues for RCTs regarding preventive pharmacologic treatments for chronic migraine are essentially identical to those of episodic migraine for the corresponding research need, but have greater challenges. Conducting RCTs with chronic migraine populations will be more difficult given the lower prevalence of the condition. Multi-site trials should be considered to recruit adequate sample sizes. Additionally, investigators might expect a greater degree of attrition among chronic migraine participants than among episodic migraine participants due to their poorer health status.

#### Chronic Migraine: Second Topical Research Need

- What is the long-term (>1 year) effectiveness of preventive pharmacologic treatments for chronic migraine? (O)

While this research question was not highly prioritized for episodic migraine, it is much more relevant for chronic migraine because these individuals often need preventive medications for long periods of time. This specific question was not addressed by the CER; however, included trials had timelines much shorter than 1 year. If chronic migraine patients are expected to take preventive medications for years, we need an improved understanding of the long-term effectiveness and harms of these medications.

##### Research Design Considerations

For several reasons, an RCT is not likely feasible for this research need. Therefore, an alternative approach is to select a sample of adults maintaining the same preventive pharmacologic treatment for over one year and evaluate headache frequency and other outcomes at set intervals throughout their treatment. This design, interrupted time series (without a comparison group) is useful to identify trends in outcomes measures during a long course of treatment. Disadvantages include the limitations in the data available, as much of it will be obtained through the patient record and the potential inconsistencies in data collected over time and between providers.

#### Chronic Migraine: Third Topical Research Need

- What is the optimal duration of preventive pharmacologic treatments for chronic migraine? (T)

As with episodic migraine, the optimal duration of preventive pharmacologic treatment is now well understood. Improved understanding should result in improved prescribing behavior. As mentioned previously, scientific evidence does not inform decisions about the optimal treatment duration. This question is relevant for chronic as well as episodic migraine populations.

##### Research Design Considerations

RCTs are the best option for addressing this research need for reasons previously discussed. Recruiting and retaining sample populations will be especially challenging due to the duration of the intervention. This should be considered when calculating sample size.

## Discussion

This FRN project refined and prioritized research needs relevant to the KQs addressed in the CER, “Preventive Pharmacologic Treatments for Migraine.”1 We conducted a deliberative process to refine and expand research gaps identified in the CER through conversations with stakeholders who represented various perspectives of expertise on the topic. This process identified eight methodological and 22 topical research questions relevant to episodic and chronic migraine. We then asked stakeholders to prioritize research questions according to their potential value. The highly ranked questions were deemed research needs. Stakeholders prioritized three methodological, six episodic migraine topical research questions, and three chronic migraine topical research needs.

Addressing methodological research needs will enhance the utility and comparability of future studies of migraine preventive pharmacologic treatments, specifically for chronic migraine. Identified episodic migraine topical research needs demonstrate the importance of an enhanced understanding the timing of preventive treatments and measuring effectiveness taking the full impact of treatments into account.

Future studies evaluating preventive pharmacologic treatments for episodic and chronic migraine should be designed to pay close attention to reducing bias as much as possible within randomized controlled trials. Double blinding is critical for this topic. Studies should be adequately powered to test hypothesized relationships, including among subgroups. Investigators should consult appropriate guidelines for controlled trials of migraine drugs.6,7

We can make general suggestions for conducting trials to address the efficacy research needs; however, resources in the field offer guidance specific to conducting trials on the pharmacologic prevention of episodic and chronic migraine. The recent update of the “Guidelines for Controlled Trials of Drugs in Migraine” from the IHS Clinical Trials Subcommittee, extensively addresses ideal conduct of trials on preventative pharmacologic interventions specific to episodic migraine.7 These guidelines discuss population selection, trial design, results, evaluation, and statistics. The “Guidelines for Controlled Trials of Prophylactic Treatment of Chronic Migraine in Adults” were published in 2008.^6^ A third recently developed resource designed to guide comparative effectiveness research that is helpful to patients making health care decisions is the Preliminary Draft Methodology Report “Our Questions, Our Decisions: Standards for Patient-Centered Outcomes Research” from the Patient-Centered Outcomes Research Institute (PCORI).8 Investigators addressing these research needs are urged to consult the relevant guidelines and reconcile guidelines with PCORI’s standards for patient-centered outcomes research when designing studies.

While the variety of perspectives brought by broad stakeholder participation is a strength of this project, we were not able to collect a representative perspective from a larger sample of stakeholders. This is a major limitation. The stakeholders participating in this project were several experts on preventive pharmacologic treatments for episodic and chronic migraine. However, the prioritized research needs reflect the opinions of these stakeholders and may not be applicable to the broader population of stakeholders on this topic.

## Conclusions

This FRN project identified several research needs (PICOTS element) thought relevant by a select group of stakeholders to move the field forward:

- How should research of pharmacologic treatment for chronic migraine define treatment success?
- How should chronic migraine populations be defined in trials?
- What biomarkers help predict treatment response?
- What is the optimal duration of preventive pharmacologic treatments for episodic migraine? (T)
- If preventive drug treatment for episodic migraine is effective but discontinued, how likely is it that the episodic migraine will return to previous levels? (I, O)
- What is the efficacy of pharmacologic treatments with respect to patient quality of life, migraine-related disability, and health care utilization in preventing episodic migraine? (O)
- What is the efficacy of multimodal treatments (pharmacologic, behavioral, etc.) in preventing episodic migraine? (I)
- Are combinations of pharmacologic treatments effective in preventing episodic migraine in patients for whom treatment with a single preventive drug has been either ineffective or intolerable? (I)
- Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for episodic migraine? (P)
- Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for chronic migraine? (P)
- What is the long-term (>1 year) effectiveness of preventive pharmacologic treatments for chronic migraine? (O)
- What is the optimal duration of preventive pharmacologic treatments for chronic migraine? (T)

## References

1 Shamliyan TA, Kane RL, Taylor FR. Migraine in Adults: Preventive Pharmacologic Treatments. Comparative Effectiveness Review No. 103. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-2007-10064-I.) AHRQ Publication No. 13-EHC068-EF. Rockville, MD. Agency for Healthcare Research and Quality. Forthcoming. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
2 NINDS Headache Common Data Element (CDE) Project. Recommendations from the Headache Preventive Therapies Subgroup: Overview of the Headache Preventive Therapies Recommendations. NINDS. 2012. www.commondataelements.ninds.nih.gov/Headache.aspx#tab=Data_Standards.
3 Lipton RB. Chronic migraine, classification, differential diagnosis, and epidemiology. Headache. Jul–Aug. Suppl 2. 2011;51:77-83. [pmid: 21770929].
4 Pringsheim T, Davenport WJ, Mackie G, et al. Canadian Headache Society guideline for migraine prophylaxis. Canadian Journal of Neurological Sciences. Mar. 2012;39(2 Suppl 2):S1-59. [pmid: 22683887].
5 Silberstein SD. Preventive migraine treatment. Neurol Clin. May. 2009;27(2):429-43. [pmid: 19289224].
6 Silberstein S, Tfelt-Hansen P, Dodick DW, et al. Guidelines for controlled trials of prophylactic treatment of chronic migraine in adults. Cephalalgia. May. 2008;28(5):484-95. [pmid: 18294250].
7 Tfelt-Hansen P, Pascual J, Ramadan N, et al. Guidelines for controlled trials of drugs in migraine: third edition. A guide for investigators. Cephalalgia. Jan. 2012;32(1):6-38. [pmid: 22384463].
8 Patient-Centered Outcomes Research Institute. Public comment draft report of the Patient-Centered Outcomes Research Institute (PCORI) Methodology Committee presented on July 23, 2012, and revised thereafter. www.pcori.org/assets/MethodologyReport-Comment.pdf.