# Stakeholders

- Werner Becker, M.D., FRCPC
  University of Calgary
  Calgary, AB, Canada
- John Beithon, M.D.
  Lakeview Clinic
  Waconia, MM
- Roger K. Cady, M.D.
  Headache Care Center
  Springfield, MI
- David W. Dodick, M.D.
  Mayo Clinic
  Phoenix, AZ
- Robert G. Kaniecki, M.D.
  University of Pittsburgh
  Pittsburgh, PA
- Richard Lipton, M.D.
  Albert Einstein College of Medicine
  Bronx, NY
- Elizabeth W. Loder, M.D.
  Faulkner Hospital
  Boston, MA
- Bray Patrick-Lake
  PFO Research Foundation
  Boulder, CO
- Linda L. Porter, Ph.D.
  National Institutes of Health
  Bethesda, MD
- Teri Robert
  American Headache Society Committee for Headache Education
  Washington, WV
- Stephen D. Silberstein, M.D., FACP
  Jefferson Headache Center
  Philadelphia, PA
- Richard Wenzel, Pharm.D.
  Saint Joseph Hospital
  Chicago, IL