# Discussion

This FRN project refined and prioritized research needs relevant to the KQs addressed in the draft CER Preventive Pharmacologic Treatments for Migraine released in April 2011.^1^ We conducted a deliberative process to refine and expand research gaps identified in the CER through conversations with stakeholders who represented various perspectives of expertise on the topic. This process identified eight methodological and 22 topical research questions relevant to episodic and chronic migraine. We then asked stakeholders to prioritize research questions according to their potential impact. The highly ranked questions were deemed research needs. Stakeholders prioritized three methodological, six episodic migraine topical research questions, and three chronic migraine topical research needs.

Addressing methodological research needs will enhance the utility and comparability of future studies of migraine preventive pharmacologic treatments, specifically for chronic migraine. Identified episodic migraine topical research needs demonstrate the importance of an enhanced understanding the timing of preventive treatments and measuring effectiveness taking the full impact of treatments into account. Identifying biomarkers helpful in predicting response to preventive pharmacologic treatment is the third methodological research need.

Future studies evaluating preventive pharmacologic treatments for episodic and chronic migraine should by design attend closely to reducing bias as much as possible within randomized controlled trials. Double blinding is critical for this topic. Studies should be adequately powered to test hypothesized relationships, including among subgroups. Investigators should consult appropriate guidelines for controlled trials of migraine drugs.26,48

We research design considerations that may assist sponsors and investigators in addressing these specific research needs; however, resources in the field provide more comprehensive guidance to conducting trials on the pharmacologic prevention of episodic and chronic migraine. The recent update of the Guidelines for Controlled Trials of Drugs in Migraine from the IHS Clinical Trials Subcommittee, extensively addresses ideal conduct of trials on preventative pharmacologic interventions specific to episodic migraine.48 These guidelines discuss population selection, trial design, results, evaluation, and statistics. The Guidelines for Controlled Trials of Prophylactic Treatment of Chronic Migraine in Adults were published in 2008.^26^ A third recently developed resource designed to guide comparative effectiveness research that is helpful to patients making health care decisions is the preliminary draft methodology report Our Questions, Our Decisions: Standards for Patient-Centered Outcomes Research from the Patient-Centered Outcomes Research Institute (PCORI).49 Investigators addressing these research needs are urged to consult the relevant guidelines and reconcile guidelines with PCORI’s standards for patient-centered outcomes research when designing studies.

While a strength of this project is the intended variety of perspectives brought by broad stakeholder participation, we were not able to collect a representative perspective from a larger sample of stakeholders. This is a major limitation. The stakeholders participating in this project were several experts on preventive pharmacologic treatments for episodic and chronic migraine. However, the prioritized research needs reflect the opinions of these stakeholders and may not be applicable to the broader population of stakeholders on this topic. Our stakeholder panel was also limited in size by standards and guidelines for statistical surveys administered by the Office of Management and Budget. These guidelines require compliance with the Paperwork Reduction Act and Information Collections Policy (44 USC 3501-3520).50 The Act was designed to (1) minimize the paperwork burden on the public, (2) assure that high quality data are obtained, and (3) minimize costs. The Act requires special approval for projects that wish to include more than nine nongovernment participants; however, the approval process exceeded the length of time available to complete this FRN project.

Finally, the finalization of the CER and related FRN project overlapped in time. This made stakeholder discussions challenging because stakeholders were provided with the draft CER Executive Summary that had not yet incorporated peer review comments. Many of these stakeholders were peer reviewers to the CER.

Future studies of preventive pharmacologic treatments for migraine in adults should seek to reduce bias as much as possible for the particular research design used. Literature examined for the draft CER provided adequate and consistent measurement and reporting of variables thought to confound or modify the effect of multidisciplinary rehabilitation programs, but because the ongoing CDE efforts appear to sufficiently address this concern, we did not include this methodological research question in our list prioritized by stakeholders.