# Conclusions

This FRN project identified several research needs thought relevant by a select group of stakeholders to move the field forward:

- How should research of pharmacologic treatment for chronic migraine define treatment success?
- How should chronic migraine populations be defined in trials?
- What biomarkers help predict treatment response?
- What is the optimal duration of preventive pharmacologic treatments for episodic migraine? (T)
- If preventive drug treatment for episodic migraine is effective but discontinued, how likely is it that the episodic migraine will return to previous levels? (I, O)
- What is the efficacy of pharmacologic treatments with respect to patient quality of life, migraine-related disability, and health care utilization in preventing episodic migraine? (O)
- What is the efficacy of multimodal treatments (pharmacologic, behavioral, etc.) in preventing episodic migraine? (I)
- Are combinations of pharmacologic treatments effective in preventing episodic migraine in patients for whom treatment with a single preventive drug has been either ineffective or intolerable? (I)
- Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for episodic migraine? (P)
- Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for chronic migraine? (P)
- What is the long-term (>1 year) effectiveness of preventive pharmacologic treatments for chronic migraine? (O)
- What is the optimal duration of preventive pharmacologic treatments for chronic migraine? (T)