# Background

## Context

This Future Research Needs (FRN) project is a followup to the recently completed Comparative Effectiveness Review (CER) “Preventive Pharmacologic Treatments for Migraine.”1 The review was motivated by uncertainty around the effectiveness, comparative effectiveness, and safety of pharmacologic treatments for the prevention of episodic or chronic migraine in adults. This FRN project identifies and prioritizes specific gaps in the current literature on this topic; additional research would aid decisionmakers.

We used a deliberative process to identify evidence gaps, translate gaps into researchable questions, and solicit stakeholder opinion on the importance of research questions. This report proposes specific research needs along with research design considerations that may help advance research in this field.

Our FRN project identifies research needs within the scope of the CER. CER authors used an analytical framework (Figure 1) to construct the following Key Questions (KQs).

Figure 1 Analytic framework

KQ = Key Question; SES = socioeconomic status

Note: KQ 1: What are the efficacy and comparative effectiveness of pharmacologic treatments for preventing migraine attacks in adults? KQ 2: What are the comparative harms from pharmacologic treatments for preventing migraine attacks in adults? KQ 3: Which patient characteristics predict the effectiveness and safety of pharmacologic treatments for preventing migraine attacks in adults?

Figure 1 presents a conceptual model and the analytical framework for the key questions within the context of the Population, Interventions, Comparators, Outcomes, and Settings. The framework includes eight headers: target Population for question as adults with migraine, pharmacological and nonpharmacological treatments for adults with migraine, intermediate outcomes such as number of headache days, and clinical outcomes such as quality of life, prevention of migraine attacks, reduction in frequency of migraine attack by at least 50% from baseline, patient satisfaction, emergency visits, and loss of working days. In general, the figure illustrates pharmacological or combined modalities versus placebo, regular care, or active control may result in intermediate outcomes and clinical outcomes. Adverse events may occur at any point after treatment is received. Treatment effects may be modified by age, gender, race, aura, prior treatment, comorbidity, family history, and access to care. The figure also gives information about the research questions. Key Question 1: What are the efficacy and comparative effectiveness of pharmacological treatments for preventing migraine attacks in adults? Key Question 2: What are the comparative harms from pharmacological treatments for preventing migraine attacks in adults? Key Question 3: Which characteristics of children predict the effectiveness and safety of pharmacological treatments for preventing migraine attacks in adults?

### Key Question 1

What are the efficacy and comparative effectiveness of pharmacologic treatments for preventing migraine attacks in adults?

a. How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared with placebo or no active treatment?
b. How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared with active pharmacologic treatments?
c. How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared with active nonpharmacologic treatments?
d. How do preventive pharmacologic treatments combined with nondrug treatments affect patient-centered and intermediate outcomes when compared with pharmacologic treatments alone?
e. How might dosing regimens or duration of treatments influence the effects of the treatments on patient-centered outcomes?
f. How might approaches to drug management (such as patient care teams, integrated care, coordinated care, patient education, drug surveillance, or interactive drug monitoring) influence results?

### Key Question 2

What are the comparative harms from pharmacologic treatments for preventing migraine attacks in adults?

a. What are the harms from preventive pharmacologic treatments when compared with placebo or no active treatment?
b. What are the harms from preventive pharmacologic treatments when compared with active pharmacologic treatments?
c. How might approaches to drug management (such as patient care teams, integrated care, coordinated care, patient education, drug surveillance, or interactive drug monitoring) influence results?

### Key Question 3

Which patient characteristics predict the effectiveness and safety of pharmacologic treatments for preventing migraine attacks in adults?

## Condition

According to the International Classification of Headache Disorders (ICHD-2), migraine is a common disabling primary headache disorder manifesting in attacks lasting 4 to 72 hours.2 Migraine headaches range from moderate to very severe3 and are sometimes debilitating.4 Migraine affects 17 percent of women and 6 percent of men.5–8

The ICHD-2 divides migraine into migraine with aura and migraine without aura. The most common type of migraine, migraine without aura, is defined as a headache that occurs at least five times per month with headaches lasting between 4 and 72 hours (untreated or unsuccessfully treated), and having a minimum number of migraine attributes [two of (a) unilateral location, (b) pulsating quality, (c) moderate or severe pain intensity, (d) aggravated by or causing avoidance of physical activity and one of (a) nausea and/or vomiting, (b) phonophobia or photophobia] and cannot be attributed to another condition.

When migraine without aura occurs on 15 or more days per month for at least 3 months and eight of the headaches meet migraine without aura criteria, without medication overuse, the complication of chronic migraine should be diagnosed.9 In practice, these definitions have often been simplified as episodic (less than 15 headache days per month) and chronic (15 or more headache days per month). The estimated prevalence of episodic migraine is nearly 12 percent.10

Chronic migraine affects 1.4 to 2.2 percent of adults.11 All migraine types significantly affect the physical, psychological, and social wellbeing of patients, and can impose serious lifestyle restrictions. Each year lost work time and diminished productivity from migraine costs American employers $225.8 billion.12–14

At a certain level of burden (which can be measured by headache frequency or levels of disability) it may be beneficial to consider preventive pharmacologic treatment. Indications for preventive pharmacologic treatment differ. The American Migraine Prevalence and Prevention expert advisory group recommends preventive treatment for those who experience two or more monthly headache attacks accompanied by disability and for those who experience four or more monthly attacks with or without accompanying disability.15 Some guidelines recommend preventive treatments for patients who have five or more migraine attacks per month,16 but others suggest it only for those who experience a headache on most days of the month.9,17 Forty percent of adults with episodic migraine might benefit from preventive medication;6,19,20 yet, only about 12 percent of adults with frequent migraines take preventive medication.5,6,19,20

Preventive medications from several drug classes are thought to affect various aspects of migraine pathophysiology.21,22 The U.S. Food and Drug Administration (FDA) has approved four drugs for migraine prevention in adults: the beta blockers propranolol and timolol, and the antiepileptic drugs topiramate and divalproex sodium.23 For prevention of chronic migraine, the FDA has approved only one drug, onabotulinumtoxinA.18 Providers also commonly prescribe off-label drugs (approved for clinical conditions other than migraine prevention), including off-label antiepileptic drugs, tricyclic antidepressants, and off-label beta blockers.24 However, many other types of drugs have been evaluated for their efficacy in migraine prevention including calcium channel blockers, glutamate blockers, and others.23,25

Preventive pharmacologic treatments aim to eliminate headache pain.26–28 Often, however, some degree of pain persists; therefore, treatment success is usually defined by a decrease in migraine frequency of 50 percent or more.3 Preventive treatments are also expected to reduce use of acute drugs and improve quality of life.6,29 Treatment safety is defined by the total rates of adverse effects and adverse effects that lead to treatment discontinuation. Between 17 and 29 percent of patients discontinue preventive migraine medication because of adverse effects such as anxiety, nausea, vomiting, sleep time reduction, drowsiness, or weakness.30,31 Drug choices in clinical practice are based on many drug-related factors such as familiarity, efficacy, and adverse effects, as well as many patient characteristics such as headache frequency, presence of aura, comorbid conditions, and patient preference.9,26,27,32–36 Often, preventive treatment is recommended for only 6 to 9 months; however, very limited research has examined migraine frequency after discontinuation of preventive treatment.3,37

### Findings of the Comparative Effectiveness Review

The CER synthesized data from eligible randomized controlled trials (RCTs) for efficacy and comparative effectiveness. Data from these RCTs and additional eligible nonrandomized studies was synthesized for harms. Key findings are summarized below.1

#### Prevention of Chronic Migraine

##### Efficacy

Only one drug for chronic migraine, onabotulinumtoxinA, was examined in more than one RCT. OnabotulinumtoxinA was better than placebo in reducing monthly migraine attack by 50 percent or more. A single RCT reported that topiramate was better than placebo in achieving a reduction of headache frequency but not better than placebo in reducing monthly migraine attacks by 50 percent or more.

##### Comparative Effectiveness

Five individual RCTs provided low-strength evidence about the comparative effectiveness of onabotulinumtoxinA versus other drugs for chronic migraine prevention. Individual RCTs examined the comparative effectiveness of onabotulinumtoxinA versus topiramate and found no significant differences in likelihood of migraine prevention or improvement in migraine disability assessment. Absolute scores of the Headache Impact Test were significantly better with topiramate than onabotulinumtoxinA; however, need for acute drugs did not differ between the two. A single RCT examined the comparative effectiveness of onabotulinumtoxinA versus divalproex sodium and found no differences between the two drugs for migraine prevention, migraine-related disability, or quality of life. A single RCT reported that propranolol added to topiramate did not effectively prevent chronic migraine in patients for whom topiramate monotherapy had failed.

##### Safety

OnabotulinumtoxinA resulted in adverse effects and treatment discontinuation due to adverse effects more often than placebo. Increase in risk of adverse effects was dose responsive. Individual RCTs demonstrated less frequent treatment discontinuation due to adverse effects with onabotulinumtoxinA than topiramate or amitriptyline.

#### Prevention of Episodic Migraine

All approved drugs were better than placebo in reducing monthly migraine frequency by ≥50 percent in individual patients. Rates of clinical response were moderate, 200 to 400 patients per 1,000 treated.

In addition to 50 percent or more reduction in monthly migraine frequency, individual RCTs of approved antiepileptic drugs and beta blockers improved other patient-centered outcomes. Topiramate demonstrated significant improvements for general health status, quality of life, and disability, with score improvements on the Medical Outcome Study Short Form 36 (SF-36) of more than 200 percent for self-reported vitality and more than 100 percent for improvement in pain and general health. Divalproex in a larger dose of 1,500 mg/day increased the likelihood of a 50 percent improvement in whether migraine attacks impaired usual activities or necessitated symptomatic medication and in reducing migraine attacks with nausea, vomiting, phonophobia, or photophobia. Topiramate and propranolol decreased use of drugs for acute migraine attacks.

Among off-label drugs, pooled analyses demonstrated that antiepileptic gabapentin, beta-blocker metoprolol, and calcium channel blocker nimodipine were better than placebo in reducing monthly migraine attacks by 50 percent or more.

Individual RCTs demonstrated that the off-label anti-epileptics carbamazepin and valproate (but not acetazolamide, lamotrigine, or oxcarbazepine) were better than placebo in reducing monthly migraine attacks by 50 percent or more. Individual RCTs demonstrated that off-label beta blockers acebutolol atenolol and nadolol (but not pindolol or alprenolol) were better than placebo in reducing monthly migraine attacks by 50 percent or more.

Individual RCTs of off-label angiotensin converting enzyme (ACE) inhibiting drugs demonstrated promising results. The ACE inhibitor captopril was examined in a single RCT. When tested in adults with comorbid hypertension and depressive symptoms for whom previous antimigraine drugs had been ineffective, the ACE inhibitor captoptil was better than placebo in achieving complete cessation of migraine, improvement in Headache Index by ≥50 percent, and reducing depression symptoms. The ACE inhibitor lisinopril was better than placebo in reducing migraine days and migraine severity in patients with episodic migraine with or without hypertension. It reduced pain measured with SF-36 but did not decrease use of drugs for acute migraine attacks.

The off-label angiotensin II antagonist (ARB) candesartan was better than placebo in achieving a clinical response defined as 50 percent or more reduction in migraine days. Candesartan also decreased migraine-related disability but had no effect on use of drugs for acute migraine attacks. In contrast, ARB telmisartan was not better than placebo in reducing monthly migraine attacks by 50 percent or more.

Pooled analysis was possible for only four paired drug comparisons for the prevention of episodic migraine. The analyses demonstrated few significant differences between individual drugs.

##### Safety

Bothersome adverse effects leading to treatment discontinuation were greater than placebo for topiramate in doses of 100 and 200 mg/day (but not 50 mg/day) and propranolol.

Among off-label drugs, pooled analyses demonstrated that the off-label antidepressant amitriptyline caused bothersome adverse effects leading to treatment discontinuation more often than placebo.

In direct comparisons of divalproex or valproate versus placebo, treatment discontinuation due to adverse effects did not differ. Pooled analysis showed no differences in treatment discontinuation with topiramate versus amitriptyline.

Indirect adjusted analyses demonstrated no differences in treatment discontinuation due to adverse effects with approved drugs or approved versus off label drugs. Exploratory Bayesian network meta-analyses demonstrated that topiramate and off-label antiepileptics and antidepressants resulted in bothersome adverse effects leading to treatment discontinuation more often than placebo. A network meta-analysis indicated that off-label ACE inhibitors and beta-blockers were the safest treatment option for adults with episodic migraine.

### Patient Characteristics

Evidence was limited to individual RCTs that examined the drug effect modification by selected patient characteristics:

- OnabotulinumtoxinA was more effective in patients with a higher mean baseline migraine frequency.
- Amitriptyline was better than placebo in reducing monthly migraine, but only in patients with depression or with baseline frequent and severe migraine.
- Topiramate was more likely to reduce migraine attacks in women but not in men according to one low-risk-of-bias RCT.
- Several post hoc subgroup analyses of topiramate versus placebo provided inconsistent evidence of the drug efficacy in respect to aura.

## Objective

Our FRN project identifies and prioritizes research needs arising from the status of current literature on efficacy, comparative effectiveness, and safety of preventative pharmacologic treatments in adults for the prevention of episodic or chronic migraine. These research needs are presented along with research design considerations and represent the opinion of a select group of stakeholders on issues on which future research has potential value to the current body of evidence.

## Evidence Gaps and Research Question Development

The CER identified gaps and biases in available evidence and made future research recommendations. Findings from the CER drew conclusions about the efficacy and comparative effectiveness of the off-label use of ACE inhibitors and angiotensin II blockers for migraine prevention that were stronger than current guidelines suggest. Because these conclusions were drawn from a small number of RCTs, future research could refute or validate the results of these early studies, assisting decisionmakers.

Additionally, well-designed randomized head-to-head clinical trials should examine the comparative effectiveness of approved drugs and the most effective off-label ACE inhibitors, angiotensin II blockers, antidepressants, and beta blockers. Future trials should examine the potential treatment modifying effects of patient age, sex, race, migraine family history, comorbidities, and prior treatment with migraine preventive drugs. The long-term efficacy of most preventive pharmacologic treatments is unknown. Evidence on improving quality of life was inconsistent across individual drugs. While common in practice, evidence for tailoring treatment to the individual patient is very limited. Future studies should strive to better capture adverse effects associated with migraine preventive drugs. Additionally, future research synthesis would benefit from trial registration and posting of results in Clinicaltrials.gov. We translated the list of Future Research Needs from the CER into researchable questions (Table 1).

Table 1 Evidence gap research questions

Methodological Research Questions
- How should treatment success be defined in research on pharmacologic treatment of episodic migraine?; - How should treatment success be defined in research on pharmacologic treatment of chronic migraine?; - What is the minimal clinically important difference for the Migraine Disability Assessment questionnaire scores?; - How should drug adverse effects be addressed in research?
Topical Research Questions (PICOTS Element)
Benefits of Treatment | [underlined: Episodic Migraine]; - What is the efficacy of angiotensin acting drugs in the prevention of episodic migraine?; - What is the comparative effectiveness (head to head trials) between angiotensin acting drugs, beta blockers, and antiepileptics for prevention of episodic migraine? (I, C); - What is the comparative effectiveness (head to head trials) of pharmacologic treatments in terms of validated measures of quality of life and migraine related disability for prevention of episodic migraine? (O); - What is the comparative effectiveness (head to head trials) of pharmacologic treatments on health care utilization (emergency department visits, hospitalizations, abortive drug utilization and overuse) for episodic migraine? (O); - What is the dose response relationship in reducing occurrence and severity of episodic migraine? (I, O); - What is the long-term (>1 year) effectiveness of pharmacologic treatments for prevention of episodic migraine? (O); - Are combinations of pharmacologic treatments effective in patients for whom pharmacologic treatments with a single preventative drug are not effective or tolerable in the prevention of episodic migraine? (I); - If drug treatment for prevention of episodic migraine is effective then discontinued, what is the likelihood of the return to previous levels of episodic migraine?; [underlined: Chronic Migraine]; - What is the efficacy of angiotensin acting drugs in the prevention of chronic migraine?; - What is the comparative effectiveness (head to head trials) between angiotensin acting drugs, beta blockers, and antiepileptics in the prevention of chronic migraine? (I, C); - What is the comparative effectiveness (head to head trials) of pharmacologic treatments in terms of validated measures of quality of life and migraine related disability for prevention of chronic migraine? (O); - What is the comparative effectiveness (head to head trials) of pharmacologic treatments on health care utilization (emergency visits, hospitalizations, abortive drug utilization and overuse) for chronic migraine? (O); - What is the dose response relationship in reducing occurrence and severity for prevention of chronic migraine? (I, O); - What is the long-term (>1 year) effectiveness of pharmacologic treatments for prevention of chronic migraine? (O); - Are combinations of pharmacologic treatments effective for prevention of chronic migraine in patients for whom pharmacologic treatments with a single preventative drug are not effective or tolerable? (I); - If drug treatment is effective in the prevention of chronic migraine but discontinued, what is the likelihood of the return to previous levels of chronic migraine?
Harms of Treatment | [underlined: Episodic Migraine]; - What are the comparative harms (head-to-head trials) between angiotensin acting drugs, beta blockers, and approved antiepileptics for prevention of episodic migraine? (I, C); - What is the dose response relationship on harms for prevention of episodic migraine? (I, O); - What is the long-term (> 1 year) safety of pharmacologic treatments for prevention of episodic migraine? (O); [underlined: Chronic Migraine]; - What are the comparative harms (head-to-head trials) between angiotensin acting drugs and beta blockers and approved antiepileptics for prevention of chronic migraine? (I, C); - What is the dose response relationship for effective drugs on harms for prevention of chronic migraine? (I, O); - What is the long-term (>1 year) safety of pharmacologic treatments for prevention of chronic migraine? (O)
Benefits/Harms Patient Subgroups | [underlined: Episodic Migraine]; - What is the comparative effectiveness (head to head trials) between angiotensin acting drugs, beta blockers, and approved antiepileptics for prevention of episodic migraine in different patient subpopulations? (P); - What are the comparative harms (head to head trials) between angiotensin acting drugs, beta blockers, and approved antiepileptics for prevention of episodic migraine in different patient subpopulations? (P); [underlined: Chronic Migraine]; - What is the comparative effectiveness (head-to-head trials) between angiotensin acting drugs, beta blockers, and approved antiepileptics for prevention of chronic migraine in different patient subpopulations? (P); - What are the comparative harms (head-to-head trials) between angiotensin acting drugs, beta blockers, and approved antiepileptics for prevention of chronic migraine in different patient subpopulations? (P)

PICOTS = population, intervention, comparison, outcome, timing, and setting.