# Ongoing Studies

NCT Number | Title | Keywords
NCT00285402 | Efficacy and Safety Clinical Trial of Intranasal AST-726 for the Prevention of Migraine | New drug
NCT01090050 | Treximet in the Treatment of Chronic Migraine | Combination drug Chronic migraine
NCT01513291 | A Study of the Safety and Efficacy of MK-6096 for Migraine Prophylaxis in Participants With Episodic Migraine (MK-6096-020) | New drug Episodic migraine
NCT00055484 | A Study to Measure the Safety and Effectiveness of Zonisamide in Subjects With Migraine Headache | Anti-epileptic
NCT00154063 | Efficacy and Safety Study of E2007 in Migraine Prophylaxis | New drug
NCT00203216 | A Clinical Study Examining the Safety and Effectiveness of a New Medication (Keppra®) for the Prevention of Migraine Headaches | New drug
NCT00210821 | Comparing the Safety and Effectiveness of Topiramate With the Safety and Effectiveness of Amitriptyline in Preventing Migraine Headaches | Comparative effectiveness
NCT00210860 | An Open Label Extension of a Study Comparing Topiramate and Amitriptyline in Migraine Prevention. | long-term safety and effectiveness
NCT00210873 | An Open Label Extension of a Study of Topiramate in Chronic Migraine. | long-term safety and effectiveness chronic migraine
NCT00216606 | The Effectiveness and Safety of Topiramate on Prevention of Chronic Migraine | Chronic migraine
NCT00216619 | The Prolonged Use of Topiramate for Preventing Migraine Headaches | long-term safety and effectiveness
NCT00242866 | Use Of GW274150 In The Prophylactic Treatment Of Migraine | New drug
NCT00297336 | An Observational Study Evaluating the Safety of Topiramate for the Prevention of Migraine | Safety
NCT00301665 | Efficacy and Safety Study of Dysport® Used for Migraine Prophylaxis | OnabotulinumtoxinA
NCT00311662 | Efficacy and Tolerability of Tonabersat in the Prophylaxis of Migraine Headache | Tonabersat
NCT00334178 | Evaluation of the Efficacy and Safety of Laxymig® as Prophylactic Treatment in Patients With Migraine | Anti-epileptic
NCT00440518 | A Study Designed to Test the Effectiveness and Safety of Treating Patients With Lacosamide for Migraine Prophylaxis | Anti-epileptic
NCT00534560 | Dose Ranging Study of the Efficacy and Tolerability of Tonabersat in the Prophylaxis of Migraine Headache | Tonabersat
NCT00742209 | Prevention Study in Adult Patients Suffering From Migraine Headaches | New drug Dose-reponse Episodic migraine
NCT00772031 | NINDS CRC Chronic Migraine Treatment Trial | topiramate and propranolol combined treatment chronic migraine
NCT01060111 | Adequate Therapy of Topiramate in Migraine | topiramate and propranolol combined treatment episodic migraine
NCT01146509 | An Evaluation Of The Efficacy And Safety Of Donepezil Hydrochloride (E2020) In Migraine Prophylaxis | donepezil hydrochloride
NCT01402479 | An Open-labeled Trial of Ramipril in Patients With Migraine | Ramipril ACE inhibitor Chronic migraine
NCT01319825 | Preventive Treatment of Episodic and Chronic Migraine | Milnacipran Antidepressant Episodic migraine Chronic migraine
NCT00443352 | A Research Study Examining The Use Of Duloxetine In The Prevention Of Migraine Headache | Duloxetine Antidepressant Episodic migraine
NCT00884663 | Candesartan Versus Propranolol for Migraine Prevention | Comparative effectiveness Candesartan (ARB) Propranolol Chronic migraine Episodic migraine
NCT01122381 | Comparison of a Drug and Placebo in the Prevention of Migraine Headaches | Ethosuximide Episodic migraine
NCT01151787 | Efficacy and Safety of Cyclobenzaprine Hydrochloride Extended Release for the Treatment of Chronic Migraine | cyclobenzaprine hydrochloride chronic migraine
NCT01225263 | Statin/Vitamin D & Migraine Study | Simvastatin statin Episodic migraine
NCT01357031 | Study With Amitriptylin to Evaluate the Efficacy of Melatonin in Treatment of Migraine | Amitriptylin Episodic migraine
NCT01432379 | BOTOX® Prophylaxis in Patients With Chronic Migraine | OnabotulinumtoxinA Chronic migraine
NCT01516892 | A Long-term Efficacy, Safety, and Tolerability Study of BOTOX® in Patients With Chronic Migraine | OnabotulinumtoxinA Chronic migraine