# Search Strategy for Ongoing Studies

Advanced Search for Intervention and Nonintervention Studies on www.ClinicalTrials.gov

Search Terms:

Prevent OR prevention OR prophylactic OR prophylaxis OR manage OR management

Condition:

Migraine

Age Group:

Adult and Senior