# Research Questions for Prioritization

Table A-1 Future Research Needs research questions for prioritization

Methodological Research Questions
M1. | How should research of pharmacologic treatments for episodic migraine define treatment success?
M2. | How should research of pharmacologic treatment for chronic migraine define treatment success?
M3. | What is the minimal clinically important difference for the Migraine Disability Assessment questionnaire scores?
M4. | How should adverse effects be measured and reported in pharmacologic studies for the prevention of chronic and/or episodic migraine?
M5. | How should chronic migraine populations be defined in trials?
M6. | Should episodic and chronic migraine be treated as one progressive disease or as conditions arising from separate physiological mechanisms?
M7. | What biomarkers help predict treatment response?
M8. | What is the appropriate timing to evaluate treatment success or failure for each drug/class of drug for preventing chronic and/or episodic migraine?
Topical Questions: Episodic Migraine
Benefits of Treatment
E1. | What is the efficacy of angiotensin acting drugs (ACE inhibitors, angiotensin receptor blockers) in preventing episodic migraine? (I)
E2. | What is the efficacy of pharmacologic treatments with respect to patient quality of life, migraine-related disability, and health care utilization in preventing episodic migraine? (O)
E3. | What is the efficacy of multimodal treatments (pharmacologic, behavioral, etc.) in preventing episodic migraine? (I)
E4. | What is the efficacy of preventive pharmacologic treatments for episodic migraine combined with treatment of existing comorbidities? (P, I)
E5. | How does patient compliance with pharmacologic treatment for episodic migraine affect efficacy? (P)
E6. | What is the comparative effectiveness (head-to-head trials) of angiotensin acting drugs, beta blockers, and antiepileptics in preventing episodic migraine? (I, C)
E7. | What is the comparative effectiveness (head-to-head trials) of preventive pharmacologic treatments for episodic migraine in terms of validated measures of quality of life and migraine-related disability? (O)
E8. | What is the comparative effectiveness (head-to-head trials) of preventive pharmacologic treatments for episodic migraine with regard to health care utilization (emergency department visits, hospitalizations, acute drug utilization, mental health visits, and medication overuse)? (O)
E9. | What is the dose-response relationship with regard to migraine occurrence and severity from preventive pharmacologic treatments for episodic migraine? (I, O)
E10. | What is the long-term (>1 year) effectiveness of preventive pharmacologic treatments for episodic migraine? (O)
E11. | What is the optimal duration of preventive pharmacologic treatments for episodic migraine? (T)
E12. | Are combinations of pharmacologic treatments effective in preventing episodic migraine in patients for whom treatment with a single preventive drug has been either ineffective or intolerable? (I)
E13. | If preventive drug treatment for episodic migraine is effective but discontinued, how likely is it that the episodic migraine will return to previous levels? (T)
E14. | What is the mechanism of action for drugs from each pharmacologic class used for episodic migraine prevention? (I)
E15. | Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for episodic migraine? (P)
Harms of Treatment
E16. | What are the comparative harms (head-to-head trials) of angiotensin acting drugs, beta blockers, and approved antiepileptics for preventing episodic migraine? (I, C)
E17. | What is the dose response relationship with regard to harms from preventive pharmacologic treatments for episodic migraine? (I, O)
E18. | What is the long-term (>1 year) safety of preventive pharmacologic treatments for episodic migraine? (O)
Benefits/Harms Patient Subgroups (Subgroups Identified: Comorbidities, Race/Ethnicity, Sex, Headache Frequency/Severity, Prior Treatment Failure Status)
E19. | What is the efficacy of preventive pharmacologic treatments in preventing episodic migraine in patient subgroups? (P)
E20. | What is the comparative effectiveness (head-to-head trials) between angiotensin acting drugs, beta blockers, and approved antiepileptics for preventing episodic migraine in patient subgroups? (P)
E21. | What are the comparative harms (head-to-head trials) of angiotensin acting drugs, beta blockers, and approved antiepileptics for preventing episodic migraine in patient subgroups? (P)
Topical Research Questions (PICOTS element): Chronic Migraine
Benefits of Treatment
C1. | What is the efficacy of angiotensin acting drugs (ACE inhibitors, angiotensin receptor blockers) in preventing chronic migraine? (I)
C2. | What is the efficacy of preventive pharmacologic treatments with respect to patient quality of life, migraine-related disability, and health care utilization in preventing chronic migraine? (O)
C3. | What is the efficacy of multimodal treatments (pharmacologic, behavioral, etc.) in preventing chronic migraine? (I)
C4. | What is the efficacy of pharmacologic treatments for chronic migraine combined with treatment of existing comorbidities? (P, I)
C5. | How does patient compliance with pharmacologic treatment for chronic migraine affect efficacy? (P)
C6. | What is the comparative effectiveness (head-to-head trials) of angiotensin acting drugs, beta blockers, and antiepileptics in preventing chronic migraine? (I, C)
C7. | What is the comparative effectiveness (head-to-head trials) of preventive pharmacologic treatments for chronic migraine in terms of validated measures of quality of life and migraine-related disability? (O)
C8. | What is the comparative effectiveness (head-to-head trials) of preventive pharmacologic treatments for chronic migraine on health care utilization (emergency department visits, hospitalizations, acute drug utilization, mental health visits, and medication overuse)? (O)
C9. | What is the dose-response relationship with regard to migraine occurrence and severity from preventive pharmacologic treatments for chronic migraine? (I, O)
C10. | What is the long-term (>1 year) effectiveness of preventive pharmacologic treatments for chronic migraine? (O)
C11. | What is the optimal duration of preventive pharmacologic treatments for chronic migraine? (T)
C12. | Are combinations of pharmacologic treatments effective in preventing chronic migraine in patients for whom treatment with a single preventive drug has been either ineffective or intolerable? (I)
C13. | If preventive drug treatment for chronic migraine is effective but discontinued, how likely is it that chronic migraine will return to previous levels? (T)
C14. | What is the mechanism of action for drugs from each pharmacologic class used for chronic migraine prevention? (I)
C15. | Which disease characteristics (duration, severity, frequency of attacks, comorbidities) affect the efficacy of preventative pharmacologic treatments for chronic migraine? (P)
Harms of Treatment
C16. | What are the comparative harms (head-to-head trials) of angiotensin acting drugs and beta blockers and approved antiepileptics for preventing chronic migraine? (I, C)
C17. | What is the dose-response relationship with regard to harms from preventive pharmacologic treatments for chronic migraine? (I, O)
C18. | What is the long-term (>1 year) safety of preventive pharmacologic treatments for chronic migraine? (O)
Benefits/Harms Patient Subgroups (Subgroups Identified: Comorbidities, Race/Ethnicity, Sex, Headache Frequency/Severity, Prior Treatment Failure Status)
C19. | What is the efficacy of preventive pharmacologic treatments in preventing chronic migraine in patient subgroups? (P)
C20. | What is the comparative effectiveness (head-to-head trials) of angiotensin acting drugs, beta blockers, and approved antiepileptics for preventing chronic migraine in patient subgroups? (P)
C21. | What are the comparative harms (head-to-head trials) of angiotensin acting drugs, beta blockers, and approved antiepileptics for preventing chronic migraine in patient subgroups? (P)

PICOTS = Population, intervention, comparison, outcome, timing, and setting.