# Abbreviations

ACE: Angiotensin converting enzyme
AHRQ: Agency for Healthcare Research and Quality
ARB: Angiotensin receptor blocker
CDE: Common Data Elements
CER: Comparative Effectiveness Review
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
FRN: Future Research Needs
ICHD-2: International Classification of Headache Disorders
IHS: International Headache Society
KQ: Key Question
NINDS: National Institute of Neurological Disorders and Stroke
PCORI: Patient-Centered Outcomes Research Institute
PICOTS: Population, intervention, comparison, outcome, timing, and setting
RCT: Randomized clinical trials
SF-36: Medical Outcome Study Short Form 36