# Results

## Evidence Gaps

Eight stakeholders returned Round 1 and 2 questionnaires. In Round 1, the stakeholders did not suggest any additional gaps within the scope of the systematic review. However, they suggested additional items they considered gaps, but that were outside the scope of the original systematic review. Because these items were not reviewed with comprehensive literature searches in the systematic review, we could not use the systematic review to verify the extent of those gaps in evidence. Therefore, they are not presented here in the Results section. However, the team thought it was important to determine how the stakeholders ranked these out-of-scope gaps compared with the in-scope gaps; therefore, we put them in the Round 2 questionnaire for priority ranking. The entire list, including in-scope and out-of-scope gaps is presented in Appendix C, along with the individual stakeholder raw scores. The out-of -scope gaps are tabled and some of them are discussed in the Discussion section.

In the final prioritization in Round 2, the stakeholders had a near unanimous consensus in ranking wound dressings as the top priority for future research needs in chronic venous leg ulcers (Table 4). The categories of treatments in Table 4 to some extent have different indications. Therefore, they are not necessarily competing with each other, and comparative studies between the categories might not be appropriate. However, we wanted to get an idea of which categories contained evidence gaps that were the most important to stakeholders, so we had our stakeholder panel prioritize the general categories.

Table 4 Prioritization of gaps in knowledge about general categories of treatment for clinically noninfected chronic venous leg ulcers

General Categories | Priority Rank (1 = highest priority)
1. Wound dressings | 1
3. Venous surgery | 2
5. Systemic antibiotics | 3

Moving from the above general categories of treatments, Table 5 lists more specific treatment gaps, along with the final priority rank determined by the stakeholders in Round 2.

Table 5 Gaps in knowledge about specific types of treatments for clinically noninfected chronic venous leg ulcers

Specific Clinical Topics | Priority Rank^*^ (1 = highest priority)
Top-tier Topics
1. Biological dressings containing living cells^†^ | 1
2. Collagen dressings for recalcitrant^‡^ ulcers^†^ | 2
3. Dressings with enzymatic debriding agents^†^ | 3
4. Laser ablation for superficial veins with reflux^†^ | 3
5. Valvular surgery for deep veins with reflux^†^ | 4
6. Ligation for incompetent perforating veins † | 4
7. Sclerotherapy for superficial veins with reflux^†^ | 5
8. Topical antibiotic- or antiseptic-impregnated dressings for clinically noninfected chronic venous leg ulcers^†^ | 5
9. Radiofrequency ablation for superficial veins with reflux^†^ | 5
Other Topics
10. Alginate fiber dressings for exudative ulcers | 6
11. Hydrogels and hydrocolloid dressings for dry ulcers | 7
12. Balloon angioplasty for obstructed deep veins | 7

* Multiple gaps with the same priority rank had tied priority rating scores.

† Indicates top-tier topic.

‡ “Recalcitrant” denotes ulcers that have persisted for more than 6 months, despite treatment.

## Future Research Needs

Taking into consideration the priorities assigned by the stakeholders to the gaps in evidence, the future research needs team developed the following list of specific research questions that need to be addressed in future research.

1. Biological dressings containing living cells. For patients with chronic, clinically noninfected venous ulcers, what effect do biological dressings in conjunction with compression compared with compression alone have on time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, and quality of life?
  - Study Design: A randomized controlled trial would be best to minimize bias and strengthen internal validity.
  - Population: The target population includes patients with clinically noninfected, chronic venous ulcers of at least 6 weeks duration or more with evidence of earlier stages of venous disease such as varicose veins, edema, pigmentation, and venous eczema.
  - Interventions: The targeted intervention includes biological advanced wound dressings (cellular, acellular). Adequate wound bed preparation such as sharp/surgical debridement must occur prior to application of these dressings to facilitate optimal outcomes. Also, standardized methods of evaluating the need for re-application need to be developed.
    ○ There are many classifications of biological dressings, including cellular and acellular skin substitutes. Dressings in this category tend to be expensive and their application intricate. Some of the biological dressings, autografts and cultured autologous skin substitutes for example, require either a donor site that further compromises patient comfort and risk of infection or a biopsy site to acquire adequate cells for growth.
    ○ Xenografts are tissues derived from one species for use on another. OASIS Wound Matrix, a type of xenograft, is an acellular dermal regeneration matrix derived from porcine small intestine submucosa. It is indicated for use in the management of partial and full thickness wounds.
    ○ Cellular dermal allografts use donor cells to create a matrix that is seeded with fibroblasts for the development of the extracellular matrix essential in wound healing. Many of these dressings are indicated for burns. Dermagraft, while studies show its benefit in the venous ulcer population, has only been approved by the Food and Drug Administration (FDA) for diabetic foot ulcers.
    ○ Lastly, composite allografts are a bilayer skin substitute containing both a dermal and epidermal layer. Apligraf uses bovine type I collagen gel and living neonatal fibroblasts as the dermal component combined with an epidermal layer composed of neonatal keratinocytes. Apligraf has been FDA approved for use on venous ulcers that have failed conventional therapy for at least four weeks.
  - Comparison: The comparison group should receive a compression system with at least two layers. It may also be beneficial to establish several comparison groups to evaluate the effects of single versus multiple dressing applications.
  - Outcome: Important outcomes include wound healing rate at 4 weeks, time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, quality of life, and total number of applications.
  - Timing: The healing rate should be assessed at 4 weeks, and 12 weeks is accepted as a standard for evaluating complete wound healing.
  - Setting: It is essential that future trials take place in a setting with wound care clinicians who understand the evaluation, treatment, and management of chronic venous ulcers. Also, surgeons skilled in wound care, surgical debridement methods, and application of biological dressing need to be part of the research team. It is imperative that wound care providers receive appropriate education about the application of biological dressings and followup patient care. This includes adequate preparation of the wound bed by debridement, controlling for infection, and the application of multi-layer compression, and an understanding of evaluation criteria to determine the indication for repeat application.
2. Collagen dressings for recalcitrant ulcers. For patients with recalcitrant, clinically noninfected venous ulcers, what effect do collagen dressings compared with compression alone have on time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, and quality of life?
  - Study Design: The best design would be a prospective, randomized, double-blind controlled trial. Prospective, randomized, double-blind controlled trials minimize information bias and can improve compliance and retention of trial participants allowing for a higher standard of scientific rigor.
  - Population: In future research, ulcers need to be characterized by duration, size, and nature of the ulcer base. For example, patients with clinically noninfected, chronic venous ulcers of 6 weeks duration or more (recalcitrant ulcers) with evidence of earlier stages of venous disease such as varicose veins, edema, pigmentation, and venous eczema need to be studied separately.
  - Interventions: The targeted intervention includes available collagen dressings. Collagen is the major protein found in the extracellular matrix, acts as a scaffold, and plays a key role in all phases of wound healing, including cellular differentiation and angiogenesis. Collagen provides the connective tissue matrix materials for fibroblast and vascular cell growth. In the recalcitrant ulcer, an increased level of inflammatory cells, metalloproteases (MMP's), can degrade the extracellular matrix and impede wound healing. Recent research theorizes that the addition of non-native collagen from a dressing to a recalcitrant wound may attract the excess MMPs allowing for growth factor stimulation and an increased production of host collagen by fibroblasts.11
    ○ The collagen within wound care products is derived from bovine, porcine, equine, or avian sources; however, the concentration and type of collagen can vary among the different dressings. Additionally, some collagen dressings can contain other additives such as alginates to mitigate exudate or antimicrobial agents to control infection. It is essential, therefore, to design trials evaluating healing rates and infection while being cognizant of the distinct differences between individual collagen dressings.
  - Comparison: The comparison group should receive a compression system with at least two layers.
  - Outcome: Important outcomes include time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, and quality of life.
  - Timing: The healing rate should be assessed at 4 weeks, and 12 weeks is accepted as a standard for evaluating complete wound healing.
  - Setting: It is essential that future trials take place in a setting with wound care clinicians who understand the evaluation, treatment, and management of chronic venous ulcers.
3. Dressings with enzymatic debriding agents. For patients with chronic, clinically noninfected venous ulcers, what effect does enzymatic debridement in conjunction with compression have on time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, and quality of life compared with autolytic, biological, or surgical debridement methods plus compression?
  - Study design: The best design is a randomized controlled trial. It would not be possible to carry out a double blind study if comparing enzymatic debridement to autolytic, biological, or surgical debridement methods. However, RCTs minimize bias and strengthen internal validity.
  - Population: The targeted population should include patients with clinically noninfected, chronic venous ulcers of at least 6 weeks duration or more with evidence of earlier stages of venous disease such as varicose veins, edema, pigmentation, and venous eczema. Additionally, there would need to be a standardized method of evaluating the condition of the wound bed to consistently report on the presence of necrotic tissue and to establish inclusion criteria.
  - Intervention: The targeted intervention includes available enzymatic debriding agents. Debridement is an intervention in preparation of the wound bed since it facilitates optimal wound healing. There are several forms of debridement: autolytic, mechanical, enzymatic, biological, and sharp/surgical. Autolytic debridement uses the body's enzymes and moisture to selectively “liquefy” necrotic tissue. It is an essentially painless process for the patient. Autolytic debridement can be achieved with occlusive or semi-occlusive dressings such as hydrocolloids, hydrogels, and transparent films. This process tends to take longer than other forms of debridement and is a viable alternative to patients who are poor surgical candidates. There is a potential risk of infection, as the wound bed is being occluded and may facilitate anaerobic bacterial growth.
    ○ Mechanical debridement uses the concept of wet to dry saline dressings. Removal of the dry dressing causes detachment of necrotic tissue from the wound bed. However, this process is non-selective and will damage healthy, granulating tissues. It is also extremely painful to the patient. Hydrotherapy is another form of mechanical debridement that can cause maceration and damage to surrounding healthy tissue. For the most part, these methods of debridement have succumbed to the more selective and less painful types of debridement.
    ○ Enzymatic debriders are chemical enzymes that help to dissolve or loosen the necrotic tissue from the wound bed. Collagenase digests the collagen in necrotic tissue while sparing healthy tissue and allowing for generation and proliferation of granulation tissue. In 2009, the FDA removed all enzymatic debriding products containing papain-urea (such as Accuzyme, Ethezyme, Panafil) due to significant side effects. Enzymatic debriders are prescription, topical medications that are costly to the patient. They can be used on wounds with large amounts of necrotic tissue. As with autolytic debridement, enzymatic debridement is a slow process and is an alternative for the patient who is a poor surgical candidate.
    ○ Sharp, bedside debridement and surgical debridement are the fastest methods to debride a wound. They are highly selective and require knowledge of excisional practices. There is a higher risk of bleeding and the patient may experience excisional pain requiring analgesia. Depending on the amount and nature of surgical debridement, operating room time and general anesthesia may be required.
  - Comparison: Comparisons could include treatment with autolytic, biological, or surgical debridement. It would be beneficial to specifically compare enzymatic debriding agents with sharp bedside /surgical debridement or biological debridement.
  - Outcome: Important outcomes include quality of the wound bed (amount of necrotic tissue and/or presence of granulation tissue), time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, complications, and quality of life.
  - Timing: The healing rate should be assessed at 4 weeks, and 12 weeks is accepted as a standard for evaluating complete wound healing
  - Setting: It is essential that future trials take place in a setting with wound care clinicians who understand the evaluation, treatment, and management of chronic venous ulcers. Also, surgeons skilled in wound care and surgical debridement methods need to be part of the research team.
4. Laser ablation. Among patients with chronic venous leg ulcers and superficial veins with reflux, is laser ablation as effective as compression therapy alone in regards to wound healing rate and recurrence?
  - Study design: Most studies available on current surgical techniques are either case series or cohort studies with no comparisons. There is a critical need to perform well-designed RCTs of adequate size that compare surgical treatments with the gold standard of compression therapy.
  - Population: The targeted population includes chronic venous ulcer patients with incompetent superficial veins documented by duplex ultrasound performed by a well-trained sonographer or accredited vascular laboratory. As indicated by the term “chronic venous ulcer,” there is usually an underlying pathophysiological problem of the affected veins. Matching the proper treatment to this underlying pathophysiology requires an accurate diagnosis using ultrasound performed by a well-trained sonographer or accredited vascular laboratory. Inadequate diagnosis and reporting of underlying pathophysiology confounds study results and interpretation.
  - Intervention: The intervention of interest here is laser ablation of superficial veins.
  - Comparison: The comparison group should receive multilayer compression therapy
  - Outcome: Important outcomes include the rate of ulcer healing, and recurrence rate.
  - Timing: Followup should continue for at least 12 months.
5. Valvular surgery. Among patients with chronic venous leg ulcer and deep veins with reflux, is valvular surgery as effective as compression therapy alone in regards to wound healing rate and recurrence?
  - Study design: An RCT would be the best design for the same reasons as noted above for question 4S.
  - Population: The targeted population includes chronic venous ulcer patients with incompetent deep veins documented by duplex ultrasound performed by a well-trained sonographer or accredited vascular laboratory.
  - Intervention: The intervention of interest here is valvuloplasty, valve transplant or valve transposition.
  - Comparison: The comparison group should receive multilayer compression therapy.
  - Outcome: Important outcomes include the rate of ulcer healing, and recurrence rate.
  - Timing: Followup should continue for at least 12 months.
6. Ligation. Among patients with chronic venous leg ulcers and perforating veins or tributaries with reflux, is ligation as effective as compression therapy alone in regards to wound healing rate and recurrence?
  - Study design: An RCT would be the best design for the same reasons as noted above for questions 4S.
  - Population: The targeted population includes chronic venous ulcer patients with incompetent perforators or incompetent tributaries documented by duplex ultrasound performed by a well-trained sonographer or accredited vascular laboratory.
  - Intervention: The intervention of interest here is ligation of incompetent perforators or incompetent tributaries.
  - Comparison: The comparison group should receive multilayer compression therapy.
  - Outcome: Important outcomes include the rate of ulcer healing, and recurrence rate.
  - Timing: Followup should continue for at least 12 months.
7. Sclerotherapy. Among patients with chronic venous leg ulcers and superficial veins or incompetent perforators with reflux, is sclerotherapy as effective as compression therapy alone in regards to wound healing rate and recurrence?
  - Study design: An RCT would be the best design for the same reasons as noted above.
  - Population: The targeted population includes chronic venous ulcer patients with incompetent superficial veins or incompetent perforators documented by duplex ultrasound performed by a well-trained sonographer or accredited vascular laboratory.
  - Intervention: The intervention of interest is sclerotherapy of incompetent superficial veins or incompetent perforators.
  - Comparison: The comparison group should receive multilayer compression therapy.
  - Outcome: Important outcomes include the rate of ulcer healing, and recurrence rate.
  - Timing: Followup should continue for at least 12 months.
8. Antiseptic impregnated dressings. For patients with clinically noninfected venous ulcers, what effect do antimicrobial/antiseptic dressings compared with compression alone have on time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, and quality of life?
  - Study Design: Studies of antimicrobial/antiseptic impregnated dressing included in the systematic review were RCTs; however, most of them did not provide a double blinded design. Prospective, randomized, double-blind controlled trials minimize information bias and can improve compliance and retention of trial participants allowing for a higher standard of scientific rigor.
  - Population: The targeted population includes patients with clinically noninfected, chronic venous ulcers of at least 6 weeks duration or more with evidence of earlier stages of venous disease such as varicose veins, edema, pigmentation, and venous eczema.
  - Intervention: The intervention of interest includes antimicrobial and antiseptic impregnated dressings with agents such as cadexomer iodine, gentian violet, Manuka honey, silver, sodium chloride, polyhexamethylene biguanide, and others. Some of the previous trials experienced high dropout rates among participants, so it will be important to monitor adherence to the assigned treatment.
    ○ Advanced wound dressings vary in their structure and function and are prescribed to meet the needs of the wound: highly exuding to desiccated. Therefore, it will be necessary to have consistent methods of evaluating and reporting wound bed characteristics as well as controlling for the vehicle dressing in which the antiseptic is impregnated. Operational definitions of clinical infection versus colonization need to be clearly elucidated. Some dressings impregnated with antiseptics may require more frequent dressing changes, not allowing compression wraps to remain in place for 7 days. Therefore, when conducting trials on antiseptic impregnated dressings, researchers may need to standardize methods of applying adequate compression while allowing for more frequent dressing changes.
  - Comparison: The comparison group should receive a compression system of at least two layers.
  - Outcome measures: Important outcomes include time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, and quality of life. Wound pain can be an indication of clinical infection. Therefore, it is necessary to develop validated and standardized scales for evaluating wound pain as well as quality of life. The development of specific and consistent methods for evaluating healing rates and quality of the wound bed will allow for synthesis of data across studies.
  - Timing: Twelve weeks is accepted as a standard for evaluating wound healing. It is essential to standardize the timing of wound pain evaluations: prior to dressing changes, during dressing changes, between dressing changes, and so forth.
  - Setting: It is essential that future trials take place in a setting with wound care clinicians who understand the evaluation, treatment, and management of chronic venous ulcers.
9. Radiofrequency ablation. Among patients with chronic venous leg ulcers and superficial veins or perforators with reflux, is radiofrequency ablation as effective as compression therapy alone in regards to wound healing rate and recurrence?
  - Study design: An RCT would be the best design for the same reasons given under question 4S.
  - Population: The targeted population includes chronic venous ulcer patients with incompetent superficial veins or incompetent perforators documented by duplex ultrasound performed by a well-trained sonographer or accredited vascular laboratory.
  - Intervention: The intervention of interest here is radiofrequency ablation of incompetent superficial veins or incompetent perforators.
  - Comparison: The comparison group should receive multilayer compression therapy.
  - Outcome: Important outcomes include the rate of ulcer healing, and recurrence rate.
  - Time: Followup should continue for at least 12 months.

Although the stakeholders prioritized surgical future research needs in the above order of interventions, we believe the most important and commonly used surgical techniques for treating venous insufficiency are: (1) radiofrequency ablation; (2) laser ablation; and (3) sclerotherapy. Ligation and valvular surgery are rarely performed. Possibly this influenced the stakeholders' interest in these types of surgery.

## Ongoing Studies

We searched for ongoing studies of chronic venous leg ulcer treatments, both those still open and those closed but not yet published (see Appendix D). We identified five studies (Appendix E) relating to cellular and acellular biological dressings, a group of dressings nearly unanimously identified by our stakeholders as a top priority for future research needs (NCT00909870, NCT00720239, NCT00425178, NCT01199588, EudraCT#: 2007-005612-91). These trials include pilot studies as well as some that appear to be underpowered. Two of the trials are ongoing. Two additional wound dressing trials were identified. One evaluates the impact of a new proprietary absorptive dressing against wound bioburden in moderate to heavily exuding venous ulcers (NCT01319123). It is not clear if this addresses one of our future research needs. However, the study sample is non-randomized and, therefore, subject to bias. The other trial (NCT01567150) is an ongoing randomized controlled trial that evaluates wound protease levels in response to a proprietary “novel wound dressing.” Wound healing (reduction in wound area and incidence of complete closure) is a secondary outcome measure. It is not clear if this addresses one of our future research needs.