# References

1 Raju S, Neglen P. Chronic venous insufficiency and varicose veins. N Engl J Med. 2009;360:2319-27. [pmid: 19474429].
2 Margolis DJ, Bilker W, Santanna J, et al. Venous leg ulcer: incidence and prevalence in the elderly. J Am Acad Dermatol. 2002;46(3):381-6. [pmid: 11862173].
3 Min RJ, Khilnani NM, Golia P. Duplex ultrasound evaluation of lower extremity venous insufficiency. J Vasc Interv Radiol. 2003;14(10):1233-41. [pmid: 14551269].
4 Bergan JJ, Schmid-Schonbein GW, Smith PD, et al. Chronic venous disease. N Engl J Med. 2006;355(5):488-98. [pmid: 16885552].
5 Van Gent WB, Wilschut ED, Wittens C. Management of venous ulcer disease. BMJ. 2010;341:c6045. [pmid: 21075818].
6 Kelly T, Yang W, Chen CS, Reynolds K, et al. Global burden of obesity in 2005 and projections to 2030. International Journal of Obesity. 2008;32:1431-7. [pmid: 18607383].
7 Mensah GA, Brown DW. An overview of cardiovascular disease burden in the United States. Health Affairs. 2007;26(1):8-48. [pmid: 17211012].
8 Zenilman J, Valle F, Malas M, et al. Chronic Venous Leg Ulcers: A Comparative Effectiveness Review of Treatment Modalities. Comparative Effectiveness Review No. 127. (Prepared by Johns Hopkins Evidence-based Practice Center under Contract No. 290-2007-10061-I.) AHRQ Publication No. 13(14)-EHC121-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
9 Whitlock EP, Lopez SA, Chang S, et al. AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2010;63:491-501. [pmid: 19540721].
10 Carey T, Sanders GD, Viswanathan M, et al. Framework for Considering Study Designs for Future Research Needs. Methods Future Research Needs Paper No. 8. (Prepared by the RTI –UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
11 DiCosmo F. The role of collagen in wound healing. Adv Skin Wound Care. 2009;22(Suppl 1):13-16.
12 Trikalinos TA, Dahabreh IJ, Lee J, et al. Methods Research on Future Research Needs: Defining an Optimal Format for Presenting Research Needs. Methods Future Research Needs Report No. 3. (Prepared by the Tufts Evidence-based Practice Center under Contract No. 290-2007-10057-I.) AHRQ Publication No. 11-EHC027-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
13 O'Meara S, Cullum NA, Nelson EA. Compression for venous leg ulcers. Cochrane Database of Systematic Reviews. 2009;(1). Art. No.: CD000265. [doi: 10.1002/14651858.CD000265.pub2].
14 Fernandez R, Griffiths R. Water for wound cleansing. Cochrane Database of Systematic Reviews. 2012;(2). Art. No.: CD003861. [doi: 10.1002/14651858.CD003861.pub3].
15 Schulz KF, Altman DG, Moher D. CONSORT 2010 statement: updated guidelines for reporting parallel group randomized trials. Ann Intern Med. 2010;152(11):726-32. www.consort-statement.org. [pmid: 20335313].
16 Tinetti ME, Studenski SA. Comparative effectiveness research and patients with multiple chronic conditions. N Engl J Med. 2011;364(26):2478-81. Epub 2011 Jun 22. [pmid: 21696327].
17 Sonnad SS, Goldsack J, Mohr P, et al. Effectiveness guidance document: methodological recommendations for comparative effectiveness research on the treatment of chronic wounds. Version 2.0 Final. Center for Medical Technology Policy. Baltimore. October. 1. 2012. www.cmtpnet.org/wp-content/uploads/downloads/2012/10/Wound-Care-2012.pdf. October 31, 2012.
18 Schultz GS, Sibbald RG, Falanga V, et al. Wound bed preparation: a systematic approach to wound management [TIME]. Wound Rep Regen. 2003;13(Suppl 4):S1-S11.
19 Gottrup F, Apelqvist J, Price P, European Wound Management Association Patient Outcome Group. Outcomes in controlled and comparative studies on non-healing wounds: Recommendations to improve the quality of evidence in wound management. Journal Of Wound Care. 2010;19(6):237-68. [pmid: 20551864].
20 Enoch S, Price P. Should alternative endpoints be considered to evaluate outcomes in chronic recalcitrant wounds?. World Wide Wounds. Oct. 2004. www.worldwidewounds.com/2004/october/Enoch-Part2/Alternative-Enpoints-To-Healing.html. April 6th, 2011.