# Methods

The aim of the future research needs project was to develop a prioritized list (or multiple lists) of research needs with considerations for potential research designs with sufficient detail for researchers and funders to use for developing research proposals or solicitations. As the resulting research is meant to improve health care decisions, stakeholders included patients/advocates, clinicians, and third-party payers.

The research needs were based on the research gaps identified in the systematic review and prioritized by the stakeholders. The methods for identifying evidence gaps and developing them into a prioritized list of research needs and feasible researchable questions involved the steps described in the immediately following subsections.

## Identification of Evidence Gaps

Evidence gaps were identified in the systematic review based on the strength of evidence, applicability, and limitations of the systematic review. We started with the Key Questions in the systematic review that had low strength of evidence or insufficient evidence. A subset of seven of the systematic review authors constituted the EPC's future research needs team. The team met multiple times and circulated by email lists of potential questions to identify gaps with specific reference to study design and the PICOTS framework (lack of information or insufficient evidence for: sub-populations/whole populations; interventions, comparisons of interventions to each other; outcomes; timing of interventions or comparisons of interventions; and settings). The EPC team used this process to develop a list of research gaps to be presented to a stakeholder panel for review, as described in following subsections.

The systematic review identified pervasive issues with the design of studies that limited their interpretation. Therefore, in addition to considering clinical evidence gaps, we asked the stakeholders to consider methodologic issues in study design, conduct of studies, reporting of outcomes, and statistical analysis.

## Engagement of Stakeholders, Researchers, and Funders

We recruited a group of eight stakeholders to participate in the identification and prioritization of evidence gaps. We sought input from patients/advocates, clinical experts, and payers.

### Stakeholder Identification

Five stakeholders were chosen from the Key Informants and Technical Expert Panel members that previously provided advice on the systematic review. They were chosen because of their expertise and familiarity with the systematic review. In addition, four new participants were chosen to fill out the stakeholder panel. Some of these were suggested by the systematic review investigators. We also searched websites of advocacy organizations to identify patient advocates who appear to be independent of payers and manufacturers according to the voting membership requirements and funding mechanisms of their organizations. The list was summarized in a table of their individual strengths and the list was presented to the team's Task Order Officer at the Agency for Healthcare Research and Quality. Stakeholders signed a conflict of interest form declaring professional activities and financial ties relevant to the clinical area. It was made clear to them that accepting the invitation and returning the conflict of interest form constituted agreement to be identified as a stakeholder contributor to the final document. Manufacturers were not solicited to be part of the stakeholder panel, but they were informed of their ability to comment during the four week public posting period for this report.

### Orienting Stakeholders

By email, we provided the stakeholders with a description of the future research needs project, and how it was related to the systematic review. We also sent them the draft of the executive summary of the systematic review. A web link to the complete draft report was provided noting that the draft was only temporarily available, and that reading the executive summary should be sufficient to meaningfully contribute to the process to identify evidence gaps and future research needs.

## Stakeholder Engagement for Additional Gap Identification and Prioritization

We used an approach performed in two rounds of engagement with the stakeholders by means of emailed questionnaires.

### Engagement Round 1 Gap List From Systematic Review and Preliminary Prioritization

The future research needs team's list of research gaps, derived from the systematic review as described above, was presented to the stakeholders by email for review and for suggestions of additional gaps within the scope of the systematic review. They were instructed to carry out a preliminary prioritization of the gaps, including any additional gaps they added to the list. To perform this preliminary prioritization, they were asked to use the criteria and ranking method described in the next subsection.

#### Criteria for Prioritization

Prior to engaging our stakeholders, we developed a draft framework consisting of criteria we considered important for prioritizing topics for future research. These draft criteria were adapted from the Agency for Healthcare Research and Quality's (AHRQ's) Effective Health Care Topic Selection Criteria9 and included:

1. Importance. The importance of the condition to patients (including consideration of whether that gap is of particular relevance to priority subpopulations such as pediatric patients, elderly patients, vulnerable and disparity populations)
2. Impact. The extent to which new research with definitive findings could potentially impact decision-making by patients, providers, or policymakers

Other prioritization criteria were determined to be less useful or relevant for Future Research Need prioritization. Uncertainty is not a useful criterion, because all identified evidence gaps are uncertain by definition. Feasibility of research on an evidence gap is a secondary concern that is independent of the need for evidence. Evidence gaps and the need for research to close such gaps are innate to the area of interest. They are gaps and needs regardless of whether research is possible or feasible. There is value in determining the absolute importance and potential impact of closing each of the gaps. The feasibility of carrying out the required research to close a gap is relative, depending on the difficulty of the research, funding sources, availability of adequate numbers of patients, incentives for researchers, the convenience of the needed length of followup, or attractiveness of the research to researchers. A question of the highest priority may secondarily be deemed worth pursuing in spite of the difficulty and cost of the research, whereas similar difficulty and cost may render research on a lesser priority gap “unfeasible.” A funding source or research group with substantial resources may consider a research question feasible, while those with limited resources may not – circumstances beyond our knowledge or control. Therefore, we did not want relative feasibility to enter into the absolute priority decisions of the stakeholders. Nevertheless, we asked the stakeholders to comment on feasibility, and we discussed it as a secondary aspect of the future research needs questions.

We did not attempt to give our two criteria quantitative values or to break these major criteria into their multiple factors for individual weighting or priority ranking and combination by a mathematical formula. That would require validation of the weights. We did not consider that practical within the scope of this project. Summing multiple factors by an arbitrary mathematical formula would give an undue appearance of objectivity, accuracy and precision. Instead we instructed the stakeholders to consider these two major criteria, importance and impact, in their priority decisions.

In the Round 1 questionnaire (Appendix A), each stakeholder was presented with three lists. List 1 presented the three general categories of chronic venous leg ulcer treatments: antibiotics, dressings, and surgery. The stakeholders were asked to rank these from 1 (highest) to 3 (lowest), based on the criteria described above.

List 2 broke these out into 8 specific populations, and asked the stakeholders to write in for each population the specific treatment that should be given the highest priority in future research. Stakeholders were also asked to suggest additional gaps within the scope of the systematic review, to indicate if they were aware of any ongoing studies addressing a gap, and to comment on the feasibility of research to address the gap. The suggested treatments were given a priority based on how many stakeholders suggested each one. This was considered the preliminary priority ranked list of gaps.

List 3 was for study design, reporting, definitions, and other methodological issues. The stakeholders were presented with 14 items, and asked to rate each one high, medium, or low priority. There was a comment box for each item, and the stakeholders were asked to add any additional methodological items.

### Engagement Round 2 Final Prioritization

The future research needs team incorporated the stakeholder comments and additional suggestions from engagement Round 1 into three lists for final prioritization (Appendix B). These lists of general treatment categories, specific treatments, and methodology issues included the preliminary rankings from the previous round. Each stakeholder was presented with these lists by email and asked to choose their top 5 choices in each list and prioritize them from 1 (highest) to 5 (lowest). We again asked them to base their ratings on the same criteria as in Round 1, importance and potential impact. Stakeholders were again asked to indicate whether they were aware of any ongoing studies addressing the gaps (duplication), and to comment on the feasibility of research addressing the gaps.

### Top-Tier Future Research Needs

A global priority ranking of the evidence gaps was calculated from the stakeholder individual ratings. The ratings of 1 (highest) to 5 (lowest) were inverted, so a priority rating of 1 corresponded to a point value of 5 for highest priority. Then these inverted individual stakeholder scores for each gap were summed and sorted from highest sum (highest priority) to lowest. If multiple gaps achieved the same sum, they were given the same priority rank. Appendix C shows the inverted scores, sums, and priority ranks. The global ranking was inspected by the future research needs team to determine if there was an obvious cutpoint between a top tier of questions and the remainder. If the global ranking was a continuum with no apparent cutpoint, the top half of the gaps or the top 10, whichever was fewer, were to be chosen as the top tier and considered the high-priority future research needs.

We also took into account the gaps that were prioritized highly by each stakeholder. After determining a preliminary top-tier cutpoint according to the score sums as described above, we reviewed and analyzed the individual stakeholder responses for the gaps on either side of the cutpoint. We then assessed which gaps had received top votes and next-to-top votes from each stakeholder, and we tracked how many of these number 1 and number 2 votes each gap near the cutpoint received. Using this method, we verified that the sum score cutpoint we chose reflected the high-priority items that the stakeholders sought to identify. If a stakeholder scored an item as one of the top two priorities, it was placed on the high-priority list automatically. There were 12 designated top priority gaps in the clinical evidence gaps list, and these were designated as the future research needs. However, two of the general categories and three of the specific treatment gaps which had been suggested by stakeholders in Round 1 were outside the scope of the systematic review. Since there was no systematic review to confirm the extent of these evidence gaps, we separated them out from the results, and they are discussed in the Discussion section. Likewise, the study design and methodology issues are not evidence gaps, and they are also discussed in the Discussion section.

## Research Question Development and Research Design Considerations

To develop the future research needs (top-tier gaps) into research questions, we divided the future research needs into the clinical areas of wound dressings, antibiotics, and surgery, and members of the team with specialty experience in these areas took charge of the appropriate group of future research needs. They developed the needs into research questions, including PICOTS information and appropriate study design issues.10 These were circulated to the entire group by email, and discussed and further developed in multiple meetings.

## Ongoing Clinical Trial Searches

To identify ongoing clinical trials that may have addressed our future research needs, we searched the World Health Organization International Clinical Trials Registry Platform (http://apps.who.int/trialsearch) and clinicaltrials.gov for trials registered since the search cutoff date of the systematic review. Each article was reviewed by two people for inclusion, applying the same inclusion/exclusion criteria used in the systematic review. For each included trial, we abstracted the trial identification number, date of registry, the expected date of completion, the study name, status, medications compared, any published results, and determined the Future Research Need the study is likely to address (Appendixes A and B).

## Analytic Framework

We used an analytic framework to describe research gaps using the same format as for the systematic review shown in the above Background section (Figure 1).

## Identification of Study Design and Methodology Problems

According to the findings in the systematic review, knowledge gaps in the field of chronic venous leg ulcer treatment were not merely due to a lack of studies, but to a lack of the use of study designs, research methodologies, and reporting capable of producing a body of interpretable studies that produce clear results that can be compared across studies and treatments. Therefore, the future research needs team examined the strength of evidence findings of the systematic review and identified specific study design and methodology issues that need to be improved in future research in this field. The future research needs team presented the stakeholders in Round 1 with 14 study design/methodology items that needed improvement. The stakeholders suggested two additional items, for a total of 16 items. It did not seem appropriate to attempt to prioritize the study design/methodology items because they are all important and mutually interdependent. For presentation purposes, the study design/methodology items were organized according to the PICOTS framework, with the addition of study design and analysis categories.