# Executive Summary

## Background

### Uncertainties Prompting Systematic Review

Chronic venous leg ulcers affect between 500,000 and 2 million persons annually, and over 50 percent of leg ulcers in the United States are classified as venous ulcers.1 They are caused by elevated venous pressure, turbulent venous flow, and inadequate venous return that can be due to occlusion or reflux in the venous system.2 The Johns Hopkins University Evidence-based Practice Center performed a systematic review3 to determine the effectiveness and safety of advanced wound dressings, systemic antibiotics, and surgical interventions relative to either compression systems or each other among patients with chronic venous leg ulcers. We defined chronic venous leg ulcers as active, noninfected ulcers present for 6 weeks or more with evidence of pre-existing venous disease. An analytic framework was used in the systematic review to describe research gaps (Figure A). Standard therapy includes aggressive compression with debridement, which heals 50 to 60 percent of venous leg ulcers.4 Widely used add-on interventions include wound dressings with active components (“advanced wound dressings”), local or systemic antimicrobials, and venous surgery.5 The comparative effectiveness and safety of these advanced wound dressings, antimicrobials and surgical procedures is unclear.

Figure A Analytic framework for comparative effectiveness of treatments

DVT=deep vein thrombosis; KQ=Key Question; PICC=peripherally inserted central catheters.

Figure A is the analytic framework diagram for the treatment of chronic venous ulcers. Chronic venous ulcers has an arrow pointing to a box with intermediate outcomes, then to a final health outcomes box. This arrow represents the key questions and treatment options. The arrow also offshoots to adverse effects of treatment and effect modifiers. The intermediate outcomes are: wound healing at four weeks, pain, and quality of wound bed (for example necrotic tissue, exudates). The final health outcomes are: time to complete wound closure, proportion of ulcers healed at twelve weeks, a wound recurrence at 24 weeks and one year, quality of life, mortality, and functional status. The adverse effects of treatment are in three columns: general, antibiotic specific, and surgery. The general adverse effects are maceration, infection, contact dermatitis, venous or arterial impairment, and cellulitis. The antibiotic-specific adverse effects are hypersensitivity, antibiotic resistance, systemic absorption, drug toxicity, C. difficile diarrhea, peripherally inserted line infection, and selection of resistant organisms. The surgery adverse effects are death, infection, bleeding, skin irritation and burning, deep vein thrombosis, and long-term recurrence reflux and ulceration. There is an arrow that runs from the key questions to the final health outcomes, and a box that comes from that line is effect modifiers. The effect modifiers are study setting, ulcer area and depth, duration of ulcer (short vs. long term), co-morbid conditions, and venous duplex testing.

### Conclusions of Systematic Review

The main findings of the systematic review are summarized in Table A. The table highlights the findings for which the strength of evidence was low, moderate, or high, while also noting that the evidence was insufficient for many of the treatments of interest.

Table A Systematic review Key Questions, findings, and strength of evidence

Key Question | Finding | Strength of Evidence^*^
KQ 1. For patients with chronic venous leg ulcers, what are the benefits and harms of using dressings that regulate wound moisture with or without active chemical, enzymatic, biologic, or antimicrobial components in conjunction with compression systems when compared with using solely compression systems? | Hydrocolloid dressings were not more effective than compression therapy alone in healing chronic venous ulcers. A collagen dressing produced faster wound healing than a non-collagen dressing. Cellular human skin equivalent dressings produced more rapid wound healing than compression therapy alone. Cadexomer iodine dressings produced modest improvements in wound healing rates and wound area compared with non-antimicrobial dressings. Silver dressings did not improve wound healing compared with non-silver dressings. For all other types of dressings, the evidence was insufficient to support a conclusion. | Low Low Moderate Moderate Moderate Insufficient
KQ 2a. For patients with chronic venous leg ulcers that do not have clinical signs of cellulitis that are being treated with compression systems, what are the benefits and harms of using systemic antibiotics when compared with using solely compression systems? | Only one study addressed this question, and it provided insufficient evidence to determine how the benefits and harms of systemic antibiotics compared with compression therapy alone. | Insufficient
KQ 2b. For patients with chronic venous leg ulcers that do not have clinical signs of cellulitis that are being treated with dressings that regulate wound moisture with or without active chemical, enzymatic, biologic, or antimicrobial components, what are the benefits and harms of using systemic antibiotics when compared with using dressings alone? | No studies addressed this question. | Insufficient
KQ 3a. For patients with chronic venous leg ulcers, what are the benefits and harms of surgical procedures aimed at the underlying venous abnormalities when compared with using solely compression systems? | Surgical procedures targeting superficial vein reflux produced similar rates of wound healing compared with compression therapy alone, but had lower ulcer recurrence rates at 3 years. Selected surgical procedures targeting perforator vein reflux produced similar rates of wound healing compared with compression therapy alone. One of these procedures (Conservative Hemodynamic treatment of Insufficiency of the Venous system in an Ambulatory setting (CHIVA)) had a lower ulcer recurrence rate. The evidence was insufficient regarding the benefits and harms of sclerotherapy, vein stripping, radiofrequency ablation, or endovenous laser therapy for superficial vein reflux, or surgery for deep vein disease. | Moderate Low to High Insufficient
KQ 3b. For patients with chronic venous leg ulcers, what are the comparative benefits and harms of different surgical procedures for a given type of venous reflux and obstruction? | The evidence was insufficient to answer this question due to the small number, small size, and poor quality of studies. | Insufficient

KQ=Key Question.

* Strength of evidence was defined as: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable or does not permit a conclusion.

### Purpose of Future Research Needs Report

We sought to identify the evidence gaps in the systematic review, to engage a representative group of stakeholders in prioritizing the gaps, and to develop future research needs questions regarding the high-priority gaps, with some discussion of appropriate study design taking into consideration the pertinent populations, interventions, comparisons, outcome measures, timing, and setting (PICOTS).

## Methods

### Evidence Gap Identification

Evidence gaps were identified as components of the Key Questions in the systematic review that had low or insufficient strength of evidence.

### Stakeholder Engagement for Additional Gap Identification and Prioritization

Stakeholder identification. Eight stakeholders participated in the identification and prioritization of evidence gaps. We sought input from patients/advocates, clinical experts, and payers. Stakeholders were identified from the Key Informants and Technical Expert Panel members from the systematic review, as well as new participants suggested by the review investigators.

Orienting stakeholders. The stakeholders were given a description of the project, the draft of the executive summary of the review, and a web link to the complete draft report.

Criteria for prioritization. We developed criteria for prioritizing gaps that were adapted from the Agency for Healthcare Research and Quality's (AHRQ's) Effective Health Care Topic Selection Criteria.6

1. Importance. The importance of the condition to patients (including consideration of whether that gap is of particular relevance to priority subpopulations such as pediatric patients, elderly patients, vulnerable and disparity populations)
2. Impact. The extent to which new research with definitive findings could potentially impact decision-making by patients, providers, or policymakers

Engagement round 1, gap list review and preliminary prioritization. In the Round 1 emailed questionnaire, each stakeholder was presented with three lists. List 1 presented the three general categories of chronic venous leg ulcer treatments: antibiotics, dressings, and surgery. The stakeholders were asked to rank these from 1 (highest) to 3 (lowest), based on the criteria described above.

List 2 broke these out into 8 specific populations, and asked the stakeholders to write in for each population the specific treatment that should be given the highest priority in future research. Stakeholders were also asked to suggest additional gaps within the scope of the systematic review, to indicate if they were aware of any ongoing studies addressing a gap, and to comment on feasibility of research to address the gap. The suggested treatments were given a priority based on how many stakeholders suggested each one. This was considered the preliminary priority ranked list of gaps.

List 3 was for study design, reporting, definitions, and other methodological issues. The stakeholders were presented with 14 items, and asked to rate each one as high, medium, or low priority. There was a comment box for each item, and the stakeholders were asked to add any additional methodological items.

Engagement round 2, final prioritization. The future research needs team incorporated the stakeholder comments and additional suggestions from engagement Round 1 into three lists for final prioritization by emailed questionnaire: (1) general treatment categories; (2) specific treatments; and (3) methodology issues. These lists included the preliminary rankings from the Round 1. Each stakeholder was asked to choose their top 5 choices in each list and prioritize them from 1 (highest) to 5 (lowest). We again asked them to base their ratings on the same criteria as in Round 1, importance and potential impact. Stakeholders were again asked to indicate whether they were aware of any ongoing studies addressing the gaps (duplication), and comment on the feasibility of research addressing the gaps.

Top-tier future research needs. A global priority ranking of the specific evidence gaps was calculated from the stakeholders' individual ratings. The global ranking was inspected by the future research needs team to determine if there was an obvious cutpoint between a top tier of questions and the remainder. If the global rankings were a continuum with no apparent cutpoint, the top half of the gaps or the top 10, whichever was fewer, were to be chosen as the top tier and considered the high-priority future research needs. After determining a preliminary top-tier cutpoint according to the score sums as described above, we reviewed and analyzed the individual stakeholder responses for the gaps on either side of the cutpoint. We then assessed which gaps had received top votes and next-to-top votes from each stakeholder, and we adjusted the cutpoint to include these number 1 and number 2 votes which indicated that at least one stakeholder felt strongly about including the gap as a high-priority need. This top tier was considered the future research needs.

### Research Question Development and Research Design Considerations

To develop the future research needs (top-tier gaps) into research questions, we divided the future research needs into the clinical areas of wound dressings, antibiotics, and surgery, and members of the team with specialty experience in these areas developed the needs into research questions, taking into consideration the PICOTS framework and appropriate study design issues.^7^ These were circulated to the entire group by email, and discussed and further developed in multiple meetings.

### Ongoing Clinical Trials Searches

To identify ongoing clinical trials that may have addressed the future research needs, we searched the World Health Organization International Clinical Trials Registry Platform (apps.who.int/trialsearch) and clinicaltrials.gov for trials registered since the search cutoff date of the review.

## Results

### Evidence Gaps

Eight stakeholders returned Round 1 and 2 questionnaires. In Round 1, the stakeholders did not suggest any additional gaps within the scope of the systematic review. However, they suggested additional items they considered gaps, but that were outside the scope of the original systematic review. Because these items were not reviewed with comprehensive literature searches in the systematic review, we could not use the review to verify the extent of the gaps in evidence on these specific items. Therefore, they are not presented here in the Results section. However, the team thought it was important to determine how the stakeholders ranked these out-of-scope gaps compared with the in-scope gaps; therefore, we included them in the Round 2 questionnaire for priority ranking. The entire list, including in-scope and out-of-scope gaps is presented in Appendix C (in the full report), along with the individual stakeholder raw scores. Some of the out-of -scope gaps are discussed in the Discussion section.

In the final prioritization in Round 2, the stakeholders had a near unanimous consensus in ranking wound dressings as the top priority for future research needs in chronic venous leg ulcers (Table B). The categories of treatments in Table B to some extent have different indications. Therefore, they are not necessarily competing with each other, and comparative studies between the categories might not be appropriate. However, we wanted to get an idea of which categories contained evidence gaps that were the most important to stakeholders, so we had our stakeholder panel prioritize the general categories.

Table B Prioritization of gaps in knowledge about general categories of treatments for clinically noninfected chronic venous leg ulcers

General Categories | Priority Rank (1 = highest priority)
1. Wound dressings | 1
2. Venous surgery | 2
3. Systemic antibiotics | 3

Moving from the above general categories of treatments, Table C lists more specific treatment gaps, along with the final priority rank determined by the stakeholders in Round 2.

Table C Gaps in knowledge about specific types of treatments for clinically noninfected chronic venous leg ulcers

Specific Clinical Topics | Priority Rank^*^ (1 = highest priority)
Top-Tier Topics
1. Biological dressings containing living cells^†^ | 1
2. Collagen dressings for recalcitrant^‡^ ulcers^†^ | 2
3. Dressings with enzymatic debriding agents^†^ | 3
4. Laser ablation for superficial veins with reflux^†^ | 3
5. Valvular surgery for deep veins with reflux^†^ | 4
6. Ligation for incompetent perforating veins † | 4
7. Sclerotherapy for superficial veins with reflux^†^ | 5
8. Topical antibiotic- or antiseptic-impregnated dressings for clinically noninfected chronic venous leg ulcers^†^ | 5
9. Radiofrequency ablation for superficial veins with reflux^†^ | 5
Other Topics
10. Alginate fiber dressings for exudative ulcers | 6
11. Hydrogels and hydrocolloid dressings for dry ulcers | 7
12. Balloon angioplasty for obstructed deep veins | 7

* Multiple gaps with the same priority rank had tied priority rating scores.

† Indicates top-tier topic.

‡ “Recalcitrant” denotes ulcers that have persisted for more than 6 months, despite treatment.

## Future Research Needs

Taking into consideration the priorities assigned by the stakeholders to the gaps in evidence, the future research needs team developed the following list of specific research questions that need to be addressed in future clinical research.

1. Biological dressings containing living cells. For patients with chronic, clinically noninfected venous ulcers, what effect do biological dressings in conjunction with compression compared with compression alone have on time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, and quality of life?
2. Collagen dressings for recalcitrant ulcers. For patients with recalcitrant, clinically noninfected venous ulcers, what effect do collagen dressings compared with compression alone have on time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, and quality of life?
3. Dressings with enzymatic debriding agents. For patients with chronic, clinically noninfected venous ulcers, what effect does enzymatic debridement in conjunction with compression have on time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, and quality of life compared with autolytic, biological, or surgical debridement methods plus compression?
4. Laser ablation. Among patients with chronic venous leg ulcers and superficial veins with reflux, is laser ablation as effective as compression therapy alone in regards to wound healing rate and recurrence?
5. Valvular surgery. Among patients with chronic venous leg ulcers and deep veins with reflux, is valvular surgery as effective as compression therapy alone in regards to wound healing rate and recurrence?
6. Ligation. Among patients with chronic venous leg ulcers and perforating veins or tributaries with reflux, is ligation as effective as compression therapy alone in regards to wound healing rate and recurrence?
7. Sclerotherapy. Among patients with chronic venous leg ulcers and superficial veins or incompetent perforators with reflux, is sclerotherapy as effective as compression therapy alone in regards to wound healing rate and recurrence?
8. Antiseptic impregnated dressings. For patients with clinically noninfected venous ulcers, what effects do antimicrobial/antiseptic dressings compared with compression alone have on time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, and quality of life?
9. Radiofrequency ablation. Among patients with chronic venous leg ulcers and superficial veins or perforators with reflux, is radiofrequency ablation as effective as compression therapy alone in regards to wound healing rate and recurrence?

Although the stakeholders prioritized surgical research needs in the above order of interventions, we believe the most important and commonly used surgical techniques for treating venous insufficiency are: (1) radiofrequency ablation; (2) laser ablation; and (3) sclerotherapy. Ligation and valvular surgery are rarely performed. Possibly this influenced the stakeholders' interest in these types of surgery.

### Ongoing Studies

We searched for ongoing studies of chronic venous leg ulcer treatments, both those still open and those closed but not yet published. We identified five studies relating to cellular and acellular biological dressings, a group of dressings nearly unanimously identified by our stakeholders as a top priority for future research needs (NCT00909870, NCT00720239, NCT00425178, NCT01199588, EudraCT#: 2007-005612-91). These trials include pilot studies as well as some that appear to be underpowered. Two of the trials are ongoing. Two additional wound dressing trials were identified. One evaluates the impact of a new proprietary absorptive dressing against wound bioburden in moderate to heavily exuding venous ulcers (NCT01319123). It is not clear if this addresses one of our future research needs. However, the study sample is non-randomized and, therefore, subject to bias. The other trial (NCT01567150) is an ongoing randomized controlled trial that evaluates wound protease levels in response to a proprietary “novel wound dressing.” Wound healing (reduction in wound area and incidence of complete closure) is a secondary outcome measure. It is not clear if this addresses one of our future research needs.

## Discussion

### Limitations

Our eight stakeholders represented a variety of perspectives and included different types of providers that are involved in the care of chronic venous leg ulcers, but included only one surgeon. The precise priority ranking of this small stakeholder group may not be fully representative of all the providers and stakeholders interested in the care of chronic venous leg ulcers.^8^ For that reason, our top tier of future research needs was large and inclusive, and we do not recommend that relative rankings within the top tier be taken as precise. It is possible that the rankings would be somewhat different if we included a larger group of stakeholders or conducted more extensive discussion with the stakeholders.

### Potential Evidence Gaps Outside Scope of Systematic Review

The stakeholders suggested some items they considered gaps, but that were outside the scope of the original systematic review (Table D). Because these items were not reviewed with comprehensive literature searches in the systematic review, we could not use the review to verify the extent of the gaps in evidence on these topics.

Table D Potential evidence gaps outside scope of systematic review

General Categories
Topical growth factors
Topical antiseptics and topical antibiotics
Specific Clinical Topics
Compression garments
Dressings with growth factors
Wound cleansing agents
Negative pressure wound therapy for edematous chronic venous leg ulcers
Arterial/venous surgery for chronic venous leg ulcers caused by mixed arterial and venous disease
Adjuvant treatments (e.g., pentoxiphylline) for all types of chronic venous leg ulcers

### Gaps in Study Design and Methodology in Research

The evidence gaps were not merely due to a lack of studies, but also because of a lack of the use of study designs, research methodologies, and reporting capable of producing studies with clear results that can be compared with each other across studies and treatments. This may be as much from lack of adherence to existing standards as from lack of standards themselves. If future research needs are addressed with the same types of poor quality studies published in the past, those gaps and needs will remain.

The future research needs team and stakeholders developed a list of 16 study design/methodology items that needed to be addressed better in studies of the treatment of chronic venous leg ulcers. This list was not intended to duplicate or replace existing study design and reporting recommendations. Rather it was meant to support existing standards and to highlight items particularly lacking or specific to this field of research.

## Conclusions

For this future research needs report, we divided the Key Questions in the systematic review into twelve individual components that constituted the evidence gaps within the scope of the review. We presented these evidence gaps to a group of eight stakeholders representing clinical experts, payer decision makers, and consumer advocates. In two engagements by emailed questionnaires, these stakeholders prioritized the evidence gaps on the basis of importance (severity and burden for patients and society) and potential impact on decision-making by patients, providers, or policy-makers. The top nine prioritized items, compared with the standard of compression, were chosen as future research needs:

- Biological dressings containing living cells
- Collagen dressings for recalcitrant ulcers
- Dressings with enzymatic debriding agents
- Laser ablation for superficial veins with reflux
- Valvular surgery for deep veins with reflux
- Ligation for incompetent perforating veins
- Sclerotherapy for superficial veins with reflux
- Topical antibiotic- or antiseptic-impregnated dressings for clinically noninfected chronic venous leg ulcers
- Radiofrequency ablation for superficial veins with reflux

We searched databases for ongoing but yet unpublished trials and found that none of these research needs are likely to be answered by ongoing research in the near future. Therefore, we consider all of these research questions as good prospects for those funding future research in this field, and we believe such research would substantially advance the treatment of chronic venous leg ulcers.

## References

1 Margolis DJ, Bilker W, Santanna J, et al. Venous leg ulcer: incidence and prevalence in the elderly. J Am Acad Dermatol. 2002;46(3):381-6. [pmid: 11862173].
2 Raju S, Neglen P. Chronic venous insufficiency and varicose veins. N Engl J Med. 2009;360:2319-27. [pmid: 19474429].
3 Zenilman J, Valle F, Malas M, et al. Chronic Venous Leg Ulcers: A Comparative Effectiveness Review of Treatment Modalities. Comparative Effectiveness Review No. 127. (Prepared by Johns Hopkins Evidence-based Practice Center under Contract No. 290-2007-10061-I.) AHRQ Publication No. 13(14)-EHC121-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
4 Bergan JJ, Schmid-Schonbein GW, Smith PD, et al. Chronic venous disease. N Engl J Med. 2006;355(5):488-98. [pmid: 16885552].
5 Carey T, Sanders GD, Viswanathan M, et al. Framework for Considering Study Designs for Future Research Needs. Methods Future Research Needs Paper No. 8. (Prepared by the RTI–UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
6 Trikalinos TA, Dahabreh IJ, Lee J, et al. Methods Research on Future Research Needs: Defining an Optimal Format for Presenting Research Needs. Methods Future Research Needs Report No. 3. (Prepared by the Tufts Evidence-based Practice Center under Contract No. 290-2007-10057-I.) AHRQ Publication No. 11-EHC027-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.