# Limitations of Systematic Review

The major limitation of the systematic review was the lack of high-quality studies of sufficient size. The evidence was mostly of low or insufficient strength. Major limitations included: lack of randomized allocation; lack of masking of outcome assessors; lack of standard outcome definitions; suboptimal comparison groups; inconsistent duration of interventions; lack of statistical analyses beyond simple healing rates; lack of sample size calculations; and large losses to followup. Thus, it could not be concluded whether many of the interventions do or do not have clinical value.