# Addendum

This report was posted for public comment from November 4, 2013 to December 2, 2013 on the Effective Health Care Web site. We received one set of thoughtful comments from the American Physical Therapy Association. The comments were related to gaps outside the scope of the original systematic review and included: the role of exercise to optimize venous pump function, optimization of general fluid balance, occupational strategies to minimize edema, inclusion of strategies for debridement and predisposing factors for venous ulcers which are located at the level of the malleoli and above. Our review involved 10,066 articles focused on the original scope of the systematic review. We agree that these issues are of importance for this very common clinical entity but our resources were limited to the original questions. Therefore no changes were made to the original report.