# Acknowledgments

We thank the members of the stakeholder panel (listed below).

## Contributors

- Laura Bolton, Ph.D.
  University of Medicine and Dentistry of New Jersey
  New Brunswick, NJ
- Anthony Disser, M.D.
  Kindred Healthcare
  Louisville, KY
- Robert Kirsner, M.D.
  University of Miami School of Medicine
  Miami, FL
- Peter Lawrence, M.D.
  University of California, Los Angeles
  Los Angeles, CA
- David Margolis, M.D.
  University of Pennsylvania
  Philadelphia, PA
- David Martin, MD
  United Healthcare
  Minneapolis, MN
- Marcia Nusgart, R.Ph.
  Patient Advocate
  Alliance of Wound Care Stakeholders
  Washington, DC
- Robert Snyder, D.P.M, C.W.S.
  Association for the Advancement of Wound Care
  Quincy, MA
- Charles Turkelson, Ph.D.
  Center for Medical Technology Policy
  Baltimore, MD