# Discussion

## Limitations

Our approach to identifying and prioritizing future research needs has some limitations. Although we attempted to engage stakeholders with a variety of backgrounds, most were clinicians with experience in the non-surgical management of chronic venous leg ulcers, and only one was a surgeon. That composition more or less reflected the composition of the providers who care for patients with chronic venous leg ulcers. Even if the composition of the stakeholder panel reflected the composition of providers in the field, it is not clear that such a “majority rules” approach would identify and prioritize the gaps in the most useful way. Others have suggested that the precise priority ranking of small, informally composed stakeholder groups may have limited validity.12 Another similarly composed group might have provided somewhat different gap identifications and rankings. For that reason, our top tier of future research needs was large and inclusive, and we do not recommend that relative rankings within the top tier be taken as precise.

It also is possible that the priority ratings would have been different if we had used a more intensive approach to engaging the stakeholders, such as in-person meetings or a series of teleconferences with stakeholders. Asking the stakeholders to read the Executive Summary of the systematic review might not have been as effective as an oral presentation and discussion of the systematic review. However, the approach we used was effective in engaging a diverse group of stakeholders in a short interval of time so that the future research needs report could be finished soon after completion of the systematic review.

The future research needs selected and presented in the Results section were constrained by the scope of the systematic review and the specific questions we asked the stakeholders to answer. Other related gaps and needs exist, as indicated by the comments that stakeholders made in the blank comment boxes we included with each item in the questionnaires. In the following section, we comment on some of those suggestions.

## Potential Evidence Gaps Outside Scope of Systematic Review

The stakeholders suggested some items they considered gaps, but that were outside the scope of the original systematic review. Because these items were not reviewed with comprehensive literature searches in the systematic review, we could not use the review to determine the extent of these potential gaps in evidence. These out-of -scope potential gaps are listed in Table 6 and some of them are discussed below.

Table 6 Potential evidence gaps outside scope of systematic review

General Categories
Topical growth factors
Topical antiseptics and topical antibiotics
Specific Clinical Topics
Compression garments
Dressings with growth factors
Wound cleansing agents
Negative pressure wound therapy for edematous chronic venous leg ulcers
Arterial/venous surgery for chronic venous leg ulcers caused by mixed arterial and venous disease
Adjuvant treatments (e.g., pentoxiphylline) for all types of chronic venous leg ulcers

### Compression Garments

For patients with chronic, clinically noninfected venous ulcers, what is the most efficacious level of compression as measured by the effects on time to complete wound closure, proportion of ulcers healed at 12 weeks, pain, quality of the wound bed, and quality of life?

A recent Cochrane review13 evaluated 39 randomized control trials and confirmed compression as effective and the standard of care for chronic venous leg ulcers. Therefore, our systematic review did not duplicate this with formal comparisons of various compression treatments among themselves, but rather accepted compression as the standard for comparing all other treatments.

The Cochrane review found multi-layer compression systems (at least two layers) to be more effective in healing venous ulcers than single compression systems, and four layers of compression were considered most effective. Elastic bandages were superior to inelastic bandages. There is more to be done in deciding exactly how much pressure is best and in establishing how to quantify and report the actual amount of pressure being applied. Direct measurement of sub-bandage pressures over the medial gaiter aspect of the leg while lying supine will diminish the effect of inter-operator variability in the amount of compression applied.

Operator skill and experience in the application of compression systems can significantly affect wound healing outcomes and patient morbidity. Wound care providers must be aware of clinical indications and contraindications related to compression therapy when choosing a compression system. An additional compression therapy to consider is intermittent pneumatic compression for the non-healing venous ulcer.

Prospective, randomized controlled trials evaluating the effects of compression on venous ulcers must control for the types of sub-bandage dressings used on the ulcer, infection, and comorbidities such as arterial disease, diabetes mellitus, and heart failure to name a few.

### Dressings With Growth Factors

For patients with chronic, clinically noninfected venous ulcers, what effect do growth factors in conjunction with compression have on time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, and quality of life compared with compression alone?

Growth factors play a significant role in all phases of wound healing by mediating processes such as inflammation, angiogenesis, extracellular matrix formation and degradation, granulation tissue formation and remodeling, epithelial cell migration and proliferation, and scar formation. The proteases found in chronic wound exudate create a hostile environment to the effectiveness of growth factors and inhibit the healing process.

Currently, Becaplermin is the only FDA approved topical growth factor wound treatment available in the United States. Becaplermin is approved for use on diabetic foot ulcers and full thickness pressure ulcers only. While the evidence related to growth factors was not appraised by the systematic review, the majority of stakeholders ranked them within their top two priorities for future research.

### Wound Cleansing Agents

For patients with chronic, clinically noninfected venous ulcers, what effect does tap water or normal saline used as wound cleansing agents in conjunction with compression have on time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, and quality of life as compared with topical disinfectants or antiseptic wound cleansing agents plus compression?

Wound cleansing agents can range from tap water, to normal saline, to topical disinfectants and antiseptics. A Cochrane review14 compared the use of tap water with other agents for cleansing wounds and found no evidence that tap water increased infection rates. However, there is a plethora of wound cleaning agents available and there is an obvious gap in the literature related to these agents. In a trial evaluating wound cleansing agents, wound dressings should be limited to dressings without antimicrobial properties.

### Topical Antibiotic or Antiseptic-Impregnated Dressings

For patients with chronic, clinically noninfected venous ulcers, what effects do topical antiseptic dressings in conjunction with compression have on time to complete wound closure, proportion of ulcers healed at 12 weeks, wound recurrence, pain, infection rates, quality of the wound bed, and quality of life compared with antiseptic-impregnated dressings plus compression?

Stakeholders identified topical antibiotics as a priority Future Research Need, but evidence concerning the effectiveness of topical antibiotics was outside the scope of the review, so some research in this area may be completed or under way, but not reflected in this report. Antiseptic-impregnated dressings include agents such as cadexomer idodine, gentian violet, honey, sodium chloride, polyhexamethylene biguanide, and others. Of those evaluated in randomized trials, only cadexomer iodine showed a modest benefit in healing rates in a Cochrane report9. A focus for future research concerning antiseptic dressings is to control for the vehicle dressing in which the antiseptic is impregnated, as well as for the characteristics of the wound bed.

### Current Minimally Invasive Endovenous Ablation Surgical Techniques And Sclerotherapy Compared With Historical And More Invasive Surgical Treatments

The only comparative evidence between surgical treatments is historical studies on invasive procedures that are no longer in common practice (superficial vein stripping, ligation, and subfascial endoscopic perforater surgery). The systematic review found historical evidence that the durability of remission was increased by these historical surgical procedures. These older invasive treatments are now mostly replaced by minimally invasive endovenous ablation techniques (radiofrequency and laser ablation) and sclerotherapy. These currently used minimally invasive techniques need to be evaluated to determine whether they produce similar improvements in durability compared with the historical surgical treatments. However, it is impractical to resurrect the old more invasive techniques, and that would potentially violate the equipoise required for ethical research. The only option may be the weaker alternative of the statistical technique of network meta-analysis, whereby treatment A (e.g., current surgical techniques) and treatment B (e.g., historical surgical techniques), which have both been compared with control treatment C (e.g., compression), but in different studies, are indirectly compared statistically through their common comparison to treatment C. This is a technique of unclear reliability, because it is difficult to know if the control treatment C was done with similar effectiveness in the different studies, particularly when they were carried out in different eras.

### Comparison of Combinations of Simultaneous and Sequential Treatments

Our stakeholders assigned high priority to future double-blind studies comparing combinations of simultaneous treatments and sequential treatments for chronic venous leg ulcers. This is especially pertinent to surgical interventions, which frequently occur in combinations and series.

## Low-Priority Evidence Gaps

### Systemic Antibiotics

Determining the appropriate use of systemic antibiotics ranked last in the list of general categories of knowledge gaps, and so it was not included as a high-priority Future Research Need in the Results section. However, we mention here some salient points regarding systemic antibiotics. The systematic review stakeholders and experts largely agreed that evidence supports use of systemic antimicrobials only in wounds with clinical evidence of infection. Therefore, the systematic review only included noninfected wounds in the Key Question on systemic antibiotics. Nevertheless, they believed that antibiotics are widely and inappropriately used in wounds without clinical infection. The systematic review identified only two RCTs of antibiotics used in chronic venous leg ulcers. Both studies were more than 20 years old, had small sample sizes, and found no benefit for systemic antibiotics. The trials had inconsistent definitions of infected wounds. Infection was often confused with colonization, and the inflammation due to edema and the underlying disease was often confused with infection. These issues need to be accounted for in designing and implementing future RCTs.

## Gaps in Study Design and Methodology in Research

In the previous systematic review,8 the team of investigators described the evidence on the effectiveness and safety of advanced wound dressings, systemic antibiotics, and venous surgical interventions, compared either with the standard of compression or with each other, in the treatment of chronic venous leg ulcers. The systematic review team noted that:

- Few randomized trials had been conducted.
- Most studies were limited by study design, study size, standard definitions, standard outcome measures, and other methodological weaknesses, rendering cross-study comparisons difficult or impossible.
- Few longitudinal observational studies of the natural history of chronic venous leg ulcers had been conducted.

As a result of the paucity of high quality studies, the systematic review concluded that there was low strength of evidence or insufficient evidence to address most components of its three Key Questions. Consequently, the review could not determine whether most of the chronic venous leg ulcer treatments studied do or do not have clinical value. In other words, the knowledge gaps in the field of chronic venous leg ulcer treatment were not merely due to a lack of studies, but to a lack of the use of study designs and research methodologies and reporting capable of producing a body of interpretable studies that produce clear results that can be compared with each other across studies and treatments. If the clinical knowledge gaps and future research needs identified in the above results section are addressed with the same types of poor quality studies published in the past, those gaps and needs will remain. Therefore, the future research needs team felt compelled to identify specific study design and methodology issues that need to be improved in future research in this field.

The future research needs team presented the stakeholders in Round 1 with 14 study design/methodology items that needed improvement. The stakeholders suggested two additional items, for a total of 16 items. Although the stakeholders were allowed to prioritize these methodology items in order for us to get an idea of what they considered the most important methodology deficits in the field, this does not mean their rankings indicate future methodology research needs, and we do not present them in a prioritized ranking here. Rather, all of these methodology items are important and mutually interdependent. Many of them are standard items of general evidence-based research widely recognized in many fields, and that have been previously codified by others.15, 16 Other items are specific to chronic wound treatment research, and these have also been itemized by others.17, 18, 19, 20 Therefore, the problems of low quality studies in the wound care field may be as much from lack of adherence to existing standards as from lack of standards themselves.

For the presentation below the methodology items are organized according to the PICOTS framework, with the addition of the study design and analysis categories. This is not intended to duplicate or replace existing study design and reporting recommendations such as those mentioned above. Rather it is meant to support existing standards and to highlight items particularly lacking in chronic venous leg ulcer research or specific to this field of research.

### Study Design

#### Standards for Studying Combinations of Simultaneous Treatments

The use of simultaneous treatments is pervasive in studies of chronic venous leg ulcers, and the synergistic effect of treatments on one another cannot be determined without appropriate statistical quantitative methods. A drawback to elucidating the influence of simultaneous treatments on one another is the need for larger sample sizes for adequate statistical power. Biologic plausibility should provide the basis for testing specific combinations of treatments.

#### Standards for Studying Sequential Treatments

In clinical practice, patients with chronic venous leg ulcers are often treated with sequential treatments without an evidence-based rationale for the order or timing. Studies of sequential treatment strategies are especially important in understanding the best use of surgery for chronic venous leg ulcers. All patients who eventually undergo venous surgery have experienced a course of non-surgical management. Randomized allocation of participants to treatment arms is especially important in this instance because of the likelihood of selection bias in its absence. Studies to evaluate sequential therapy should have a standardized approach to the sequential treatment arm(s) in which all patients in a given arm receive the same intervention based on the same parameters (e.g., the type of surgery is based on ultrasound and failure to respond to an intervention defined in a standardized fashion). A drawback to studying sequential combinations of treatments includes the complexity of the design and the delivery of interventions.

#### Standards for Allocating Patients to Treatment Groups

Randomization to intervention is the best method for limiting selection bias and confounding in intervention studies. This issue is extremely important in a condition such as chronic venous leg ulcers in which the severity of disease is apparent and can thus easily influence treatment allocation in the absence of randomized, concealed allocation. Issues around selection bias are even more prominent when comparing surgical interventions to non-surgical interventions, given that surgery is typically indicated for more recalcitrant ulcers. Patients and their providers may have strong opinions about surgical versus non-surgical interventions, which can make obtaining consent for randomization difficult.

#### Standards for Estimating Proper Sample Sizes

Well-developed statistical methods for estimating the size of samples needed to answer research questions are readily available and should be used to design all studies of treatments for chronic venous leg ulcers.

#### Standards for Recruiting Patients

Ethical methods for obtaining patients' informed consent to be randomized into a treatment arm of a study—and for recording their baseline characteristics before randomization—are readily available and should be used in all randomized studies of venous ulcer treatments.

### Population

#### Standards for Describing Participating Patients and Their Ulcers

Reporting of patient characteristics is integral to evaluating a study's external and internal validity. Knowing the characteristics of participating patients and their ulcers facilitates the generalizability of study results to different patient populations. The duration and size of an ulcer appear relevant to the effectiveness of certain dressings. Standard terms that describe wound bed appearances and a means of quantifying wound bed tissues need to be developed. Such characteristics should be described for intervention and comparison groups to determine and adjust for imbalances of confounders across treatment arms. Ultimately, describing participating patients will help to identify further relevant gaps in research among demographic and clinical groups of patients.

#### Standards for Defining and Classifying “Chronic Venous Leg Ulcers”

Universal definitions of common types of chronic venous leg ulcers are needed. The definitions should address physical characteristics, location, bacteriology, duration and relation to venous flow. Ideally, the definitions would be developed by consensus, promulgated, and used in all studies of the treatment of such ulcers.

### Comparisons

#### Standards for Selecting Valid Comparison Groups

The use of an appropriate comparison group is necessary for reducing confounding and for understanding the performance of the active intervention relative to the comparison treatment. The use of appropriate comparison groups does require additional resources but is necessary to understand how study results compare with the current standard of care.

### Outcome Measures

#### Standards for Measuring Outcomes

The valid and reliable measurement of outcomes is a major issue in studies of chronic venous leg ulcers. Most studies of chronic venous leg ulcers should employ measures that have a subjective component. As such, proper use of validated measures which show acceptable inter- and intra-rater reliability is critical to precision of observation. There is a need to develop standards for measuring healing rates as a valid intermediate outcome. For this outcome, as well as for time to complete healing, we need to agree on definitions of epithelialization and what method(s) are acceptable to demonstrate this result. Validated measures of patient-reported outcomes, such as pain and quality of life, and standards for the unbiased administration of these measures should be adopted or developed.

#### Standards for Selecting Important Outcomes (Primary and Secondary) and Measures

Such outcomes may include healing rates and time to complete healing, as well as safety, patient-reported and other secondary outcomes. A tool to evaluate quality of life in the venous ulcer population needs to be validated and used consistently.

#### Standards for Reporting Harms

All patients enrolled in studies of chronic venous ulcer treatment should be monitored actively to detect any adverse events that could be related to their treatment. All such events should be described in the articles that report the results of such studies.

### Timing

#### Standards for Establishing the Needed Duration of Followup

Studies should be designed to follow patients long enough to ascertain the completeness and durability of ulcer healing.

### Statistical Analysis

#### Standards for Analyzing Data

Standards for analyzing study data should include estimating power and sample size, intention-to-treat analysis, and statistical methods to account for confounding, effect modification and clustering of patients.

#### Standards for Analyzing Interactions Between Simultaneous Treatments

Well-developed statistical techniques should be employed to analyze potentially complex interactions between simultaneous treatments in this domain of research.

#### Standards for Reporting All Patients' Flow Through Studies

All patients enrolled in studies should be tracked throughout the studies, and their “flow” through the studies should be reported in journal articles. “Completers analyses” are known to be biased toward showing a benefit of the active intervention, as patients who have benefitted are more likely to complete a study. Knowledge of the reasons for losses to followup (e.g., adverse events) are useful for clinicians' and researchers' understanding of the relative effects of interventions. Analytic techniques to handle missing data are helpful and, if used appropriately, can reduce the chance of bias.

#### Standards for Reporting Information About Patients Lost to Followup

Studies should describe all patients enrolled and report all losses to followup. Intention-to-treat analysis and emphasis on retention of enrolled participants are essential.