# Conclusions

Our purpose was to identify and prioritize the evidence gaps indicated in the Johns Hopkins University Evidence-based Practice Center systematic review of treatments for chronic venous leg ulcers.8 The goal and scope of that review was to determine the effectiveness and safety of advanced wound dressings (Key Question 1), systemic antibiotics (Key Question 2), and surgical interventions (Key Question 3), compared with either each other or to compression systems (as the standard of care), among patients with chronic venous leg ulcers. This particular category of chronic wounds was chosen because its homogeneity would enhance the ability to make comparisons across studies. For all of the Key Questions, there were few, if any, well conducted randomized studies that provided moderate to high quality evidence. The review rated the strength of evidence of most aspects of all three Key Questions as low or insufficient. For the purposes of the future research needs reports, low or insufficient strength of evidence is the definition of an evidence gap. Therefore, for this future research needs report we divided the Key Questions into twelve individual components that constituted the evidence gaps within the scope of the review.

We presented these evidence gaps to a group of stakeholders representing clinical experts, payer decision makers, and consumer advocates. In two engagements by emailed questionnaires, these stakeholders prioritized the gaps on the basis of importance (severity and burden for patients and society) and potential impact on decision-making by patients, providers, or policy-makers.

In terms of the general categories of treatments in the three Key Questions of the systematic review, the stakeholders ranked them: (1) wound dressings, (2) venous surgery, and (3) systemic antibiotics.

Of the twelve specific evidence gaps, we chose the top nine prioritized by the stakeholders, based both on the number of stakeholders voting for a gap, as well as the fact that some stakeholder ranked it as their highest, or next highest priority. These top-tier future research needs are:

- Biological dressings containing living cells
- Collagen dressings for recalcitrant ulcers
- Dressings with enzymatic debriding agents
- Laser ablation for superficial veins with reflux
- Valvular surgery for deep veins with reflux
- Ligation for incompetent perforating veins
- Sclerotherapy for superficial veins with reflux
- Topical antibiotic- or antiseptic-impregnated dressings for clinically noninfected chronic venous leg ulcers
- Radiofrequency ablation for superficial veins with reflux

We consider our process valid for identifying and selecting these top research needs, however, we don't know that another similarly representative group of stakeholders would have chosen this particular order. Therefore, we advise the reader not to place undue emphasis on this particular order, but to consider all of these high-priority future research needs.

We searched databases for ongoing but yet unpublished trials and did not determine that any of these research needs are likely to be answered by ongoing research in the near future. Therefore, we consider all of the listed future research needs as good prospects for those funding future research in this field, and we believe such research would substantially advance the treatment of chronic venous leg ulcers.

The stakeholders also suggested eight additional items they considered gaps, but that were outside the scope of the original systematic review. Because these items were not reviewed with comprehensive literature searches in the systematic review, we could not use the review to elaborate on the extent of these potential gaps in evidence. However, we presented a brief discussion of these additional potential evidence gaps in which the stakeholders were interested.

The lack of high quality evidence for many modes of therapy in the systematic review does not mean that those interventions do not work; rather there was not quality data to sustain such claims. The evidence gaps in this field were not merely due to a lack of studies, but to a lack of knowledge about or adherence to study designs, research methodologies, and reporting standards capable of producing a body of interpretable studies with clear results that can be compared across studies and treatments. If the future clinical research needs we identified are addressed with the same types of poor quality studies published in the past, those gaps and needs will remain. Therefore, the future research needs team identified specific study design and methodology issues that need to be improved in future research on treatments for chronic venous leg ulcers.