# Background

## Context

### Description of Disease

Venous leg ulcers are caused by elevated venous pressure, turbulent venous flow, and inadequate venous return that can be due to venous occlusion and/or venous reflux.1 These ulcers affect the full thickness of the skin and are most commonly located at the ankle. Chronic venous disorders should be distinguished from other causes of skin ulcers such as arterial ischemia, pressure, diabetic neuropathy, and trauma as the management of these types of ulcers varies. Identification of the specific venous defect predisposing to a venous ulcer can often be determined with imaging and may facilitate personalized and more effective treatment of the ulcer. We defined a chronic venous leg ulcer as an active ulcer present for 6 weeks or more with evidence of earlier stages of venous disease such as varicose veins, edema, pigmentation, and venous eczema but without active infection.

### Clinical Context

Venous leg ulcers affect between 500,000 and 2 million persons annually; over 50 percent of leg ulcers in the United States are classified as venous ulcers.2 Risk factors for chronic venous disease include: age; underlying conditions associated with poor venous return (such as congestive heart failure and obesity); and conditions associated with primary destruction of the venous system (such as prior deep venous thrombosis, injection drug use, phlebitis, and venous valvular dysfunction).1 The diagnosis of venous ulcers is made clinically on the basis of anatomic location, morphology, and characteristic skin changes. Clinical diagnosis is confirmed by functional assessment of the venous system, most commonly by venous duplex ultrasound.3 Chronic venous leg ulcers are cared for by a variety of practitioners in different disciplines, who use a wide variety of interventions. The current standard clinical approach to therapy includes aggressive compression of the lower limb with debridement of the ulcer, which heals 50 to 60 percent of venous leg ulcers.4 Widely used add-on interventions include wound dressings with active components (defined here as “advanced wound dressings”), local or systemic antimicrobials, and venous surgery.5

### Current Uncertainties and Controversies in Treatment of Chronic Venous Leg Ulcers That Prompted Systematic Review

Chronic venous leg ulcers are a significant source of morbidity and mortality around the world,5 and their prevalence will only increase as the population ages and risk factors such as obesity6 and congestive heart failure7 continue to rise. This public health burden necessitates identification of the best first- and second-line therapies for these ulcers. While technology and innovation have resulted in a proliferation of add-on interventions, the comparative effectiveness and safety of these advanced wound dressings, antimicrobials and surgical procedures in current use is unclear. The added benefit of these therapies to standard care with compression and debridement also remains to be established.

## Systematic Review Summary

### Objectives of Systematic Review

The Johns Hopkins University Evidence-based Practice Center (EPC) performed a systematic review8 to determine the effectiveness and safety of advanced wound dressings, systemic antibiotics, and surgical interventions compared with either each other or with compression systems (as the standard of care) among patients with chronic venous leg ulcers.

The authors of the systematic review narrowed the focus to venous ulcers to minimize confounding variables. The other varieties of common cutaneous ulcers such as diabetic, atherosclerotic, neuropathic and pressure ulcers have multiple underlying confounding comorbidities. The initial goal was to examine three of the major therapeutic interventions used in ulcer care in a relatively medically uncomplicated homogeneous population. The findings are summarized in Table 1.^8^

Table 1 Systematic review Key Questions, findings, and strength of evidence

Key Question | Finding | Strength of Evidence^*^
KQ 1. For patients with chronic venous leg ulcers, what are the benefits and harms of using dressings that regulate wound moisture with or without active chemical, enzymatic, biologic, or antimicrobial components in conjunction with compression systems when compared with using solely compression systems? | Hydrocolloid dressings were not more effective than compression therapy alone in healing chronic venous ulcers. A collagen dressing produced faster wound healing than a non-collagen dressing. Cellular human skin equivalent dressings produced more rapid wound healing than compression therapy alone. Cadexomer iodine dressings produced modest improvements in wound healing rates and wound area compared with non-antimicrobial dressings. Silver dressings did not improve wound healing compared with non-silver dressings. For all other types of dressings, the evidence was insufficient to support a conclusion. | Low Low Moderate Moderate Moderate
KQ 2a. For patients with chronic venous leg ulcers that do not have clinical signs of cellulitis that are being treated with compression systems, what are the benefits and harms of using systemic antibiotics when compared with using solely compression systems? | Only one study addressed this question, and it provided insufficient evidence to determine how the benefits and harms of systemic antibiotics compared with compression therapy alone. | Insufficient
KQ 2b. For patients with chronic venous leg ulcers that do not have clinical signs of cellulitis that are being treated with dressings that regulate wound moisture with or without active chemical, enzymatic, biologic, or antimicrobial components, what are the benefits and harms of using systemic antibiotics when compared with using dressings alone? | No studies addressed this question. | Insufficient
KQ 3a. For patients with chronic venous leg ulcers, what are the benefits and harms of surgical procedures aimed at the underlying venous abnormalities when compared with using solely compression systems? | Surgical procedures targeting superficial vein reflux produced similar rates of wound healing compared with compression therapy alone, but had lower ulcer recurrence rates at 3 years.Selected surgical procedures targeting perforator vein reflux produced similar rates of wound healing compared with compression therapy alone. One of these procedures (Conservative Hemodynamic treatment of Insufficiency of the Venous system in an Ambulatory setting [CHIVA]) had a lower ulcer recurrence rate. The evidence was insufficient regarding the benefits and harms of sclerotherapy, vein stripping, radiofrequency ablation, or endovenous laser therapy for superficial vein reflux, or surgery for deep vein disease. | Moderate Low to High Insufficient
KQ 3b. For patients with chronic venous leg ulcers, what are the comparative benefits and harms of different surgical procedures for a given type of venous reflux and obstruction? | The evidence was insufficient to answer this question due to the small number, small size, and poor quality of studies. | Insufficient

KQ=Key Question

* Strength of evidence was defined as: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable or does not permit a conclusion, DVT=deep vein thrombosis; KQ=Key Question; PICC=peripherally inserted central catheter

## Analytic Framework

We used an analytic framework to describe research gaps using the same format as for the systematic review (Figure 1).

Figure 1 Analytic framework for comparative effectiveness of treatments

DVT=deep vein thrombosis; KQ=Key Question; PICC=peripherally inserted central catheter

Figure 1 is the analytic framework diagram for the treatment of chronic venous ulcers. Chronic venous ulcers has an arrow pointing to a box with intermediate outcomes, then to a final health outcomes box. This arrow represents the key questions and treatment options. The arrow also offshoots to adverse effects of treatment and effect modifiers. The intermediate outcomes are: wound healing at four weeks, pain, and quality of wound bed (for example necrotic tissue, exudates). The final health outcomes are: time to complete wound closure, proportion of ulcers healed at twelve weeks, a wound recurrence at 24 weeks and one year, quality of life, mortality, and functional status. The adverse effects of treatment are in three columns: general, antibiotic specific, and surgery. The general adverse effects are maceration, infection, contact dermatitis, venous or arterial impairment, and cellulitis. The antibiotic-specific adverse effects are hypersensitivity, antibiotic resistance, systemic absorption, drug toxicity, C. difficile diarrhea, peripherally inserted line infection, and selection of resistant organisms. The surgery adverse effects are death, infection, bleeding, skin irritation and burning, deep vein thrombosis, and long-term recurrence reflux and ulceration. There is an arrow that runs from the key questions to the final health outcomes, and a box that comes from that line is effect modifiers. The effect modifiers are study setting, ulcer area and depth, duration of ulcer (short vs. long term), co-morbid conditions, and venous duplex testing.

## Limitations of Identified Literature in Systematic Review

The systematic review8 screened the titles and abstracts of more than 10,000 published articles, and only 66 met the criteria for inclusion in the analysis. Few well-designed randomized controlled trials (RCTs) were found that addressed the comparative effectiveness of treatments for chronic venous leg ulcers. The RCTs generally did not report on allocation concealment, and did not mask patients or outcome assessors to treatment assignment. The review was expanded to include observational studies, but these studies were largely limited to convenience populations, which, by definition, carry with them a substantial risk of bias. Overall, the studies that addressed the topic were heterogeneous and had major problems that limited our ability to make firm conclusions about the effectiveness and safety of treatments for chronic venous leg ulcers. Major limitations of the published data threatened both internal and external validity. These limitations included the lack of standard definitions of chronic venous leg ulcers, inconsistent outcome measures, suboptimal comparison groups, and inconsistent duration of interventions. Deficiencies included inadequate patient enrollment, inadequate characterization of important clinical variables, poor construction of control groups, variable lengths of study time, imprecise definitions of complete wound healing, bias and inadequate blinding, and lack of standards for measuring wound healing rates, pain, and quality of life. Studies often had large losses to followup or did not report on this. Many of the studies also did not report statistical analyses beyond simple healing rates, stratification or adjustment to account for potential confounding variables, or sample size calculations. Most studies were small and therefore had limited statistical power. Historically, case series and limited trials have been the predominant type of publications in this area of research. Furthermore, many of the interventions are classified as devices, where regulatory approval appears less rigorous than for drugs.

## Evidence Gaps

Questions in the systematic review that had low or insufficient strength of evidence are defined as evidence gaps. Based on that definition, Table 2 breaks out the individual evidence gaps determined from the results of the systematic review by the authors of this future research needs report.

Table 2 Gaps identified in systematic review

Key Question No. | Evidence Gaps | Strength of Evidence^*^
1a | What is the comparative effectiveness in healing by hydrocolloid dressings vs. compression? | Low
1b | What is the comparative effectiveness in healing by hydrocolloid dressings vs. other dressings? | Insufficient
1c | What is the comparative effectiveness in healing by transparent films vs. compression? | Insufficient
1d | What is the comparative effectiveness in healing by collagen dressings vs. other types of dressings? | Low
1e | What is the comparative effectiveness in healing by alginate dressings vs. compression? | Insufficient
2a | What are the benefits and harms of systemic antibiotics compared with compression? | Insufficient
2b | What are the benefits and harms of systemic antibiotics compared with advanced wound dressings? | Insufficient
3a | What are the benefits and harms of minimally invasive ligation of insufficient saphenous vein tributaries or open perforator ligation, compared with compression? | Low
3b | What are the benefits and harms of sclerotherapy, vein stripping, radiofrequency ablation, or endovenous laser therapy for superficial vein reflux, or surgery for deep vein disease, compared with compression? | Insufficient
3c | What are the relative benefits and harms of different surgical interventions? | Insufficient

* Strength of evidence was defined as: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable or does not permit a conclusion.

Comparing Tables 1 and 2, it can be seen that most of the Key Questions in the systematic review could not be answered well because of the limited quality and amount of evidence. It is promising that some of the more recent trials were of higher quality. An underlying cause of this lack of useful evidence is not lack of asking appropriate questions but rather a consequence of poor design and execution of the experimental protocols, and poor reporting. Furthermore, the team conducting the systematic review gained an appreciation of the numerous factors complicating the study of venous disease. Variations in patient characteristics might influence assignment of therapeutic interventions. Complicating variables included: ulcer size, ulcer duration, history of recurrence of lesions over time, and appearance of the ulcer base (dry versus presence of excessive moisture, hemorrhagic versus avascular, presence of fibrosis around the rim). Studies rarely reported much detail about these factors. For example, in evaluating dressings, some are engineered to absorb moisture whereas others are aimed at hydrating the base. The lack of this information made it difficult to analyze the effectiveness of the different types of dressings.

In addition, there was little concordance of experimental design across the extensive literature reviewed. Definitions of “healed and healing rates” varied substantially over duration of time. Papers often lacked power calculations for the number of patients or prospective strategies to deal with patient dropouts. Similarly, there was no agreed upon definition of durability of healing or length of followup period. Patient-reported outcomes were often uninterpretable because there were no standard metrics for assessing pain, quality of life, or adverse reactions. A substantial number of multi-center investigations were performed without evidence of standardization of observation between cooperating study sites. Evaluations of surgical interventions were often serial case series by surgeons without a control group or adequate blinding.

Venous ulcer research was often confounded by the conduct of the studies. Individual caregivers may vary in their ability to apply dressings or compression, and surgeons also have variable skill in performing procedures. To compound the complexity further, those involved in treatment were often also the evaluators of progress, which presents problems of blinding and bias.

The analysis of data varied substantially, and some studies lacked any statistical analysis. Many other studies used inadequate statistical tests. Different reporting methods prevented direct comparison of information, so meta-analysis was not possible.

Because of all these pervasive study design, methodology, and reporting issues, the future research needs team decided to list the methodology gaps observed in the systematic review (Table 3). In doing so, the PICOTS framework was used, with the addition of study design and analysis items. These two lists, the clinical evidence gaps (above) and the study design and methodology gaps (below), were the starting point for the future research needs report that follows.

Table 3 Gaps in study design and research methodology limiting conclusions of systematic review

Category | Study Design or Methodology Gap
Study Design | Estimation of sample size to achieve sufficient power; conduct and reporting of randomized allocation, allocation concealment, masking of outcome assessors, design and delivery of interventions sufficient for replication, and patient retention
Patients | Standardized characterization and reporting of patient and wound characteristics
Comparisons | Adequate comparison groups detailing level and method of compression
Outcomes | Standard definitions and measurement, including safety outcomes
Timing | Standard, sufficient duration of followup to permit evaluation of recurrence
Statistical Analyses | Appropriate statistical testing, accounting for confounding, stratification, handling of missing data and losses to followup