# Search Strategies for Ongoing Studies

Resource URL | Search Parameters | Search Terms/Strategy
ClinicalTrials.gov clinicaltrials.gov | Advanced search, Conditions field used | Chronic venous ulcer OR venous leg ulcer OR venous ulcer
EU Clinical Trials Register www.clinicaltrialsregister.eu | Not applicable | Chronic venous ulcer OR venous leg ulcer OR venous ulcer
NIH Reporter projectreporter.nih.gov/reporter.cfm | Projects field searched | Chronic venous ulcer OR venous leg ulcer OR venous ulcer
Canadian Institutes of Health Research www.cihr-irsc.gc.ca/ | Funding Decisions Data field searched | Chronic venous ulcer OR venous leg ulcer OR venous ulcer
World Health Organization International Clinical Trials Registry Platform Search Portal apps.who.int/trialsearch/ | Searched Condition field, Recruitment status = ALL | Chronic venous ulcer OR venous leg ulcer OR venous ulcer