# Chronic Venous Leg Ulcer Future Research Needs Stakeholder Priority Master List

Q# | Topic | Stakeholder 1 | Stake-holder 2 | Stake-holder 3 | Stake-holder 4 | Stake-holder 5 | Stake-holder 6 | Stake-holder 7 | Stake-holder 8 | Sum (highest value = highest priority) | Priority Rank (1 = highest priority)
| | These scores have been inverted so that the highest value (5) is the highest priority.
| List 1. Gaps in Knowledge about the [underlined: General Categories] of Treatments for Clinically Noninfected Chronic Venous Ulcers
1 | Wound dressings | 5 | 5 | 4 | 5 | 5 | 5 | 2 | 5 | 36 | 1
2 | Topical growth factors | 2 | 3 | 3 | 4 | 3 | 3 | 3 | 3 | 24 | 2
3 | Venous surgery | 3 | 1 | 5 | 3 | 4 | 1 | 1 | 4 | 22 | 3
4 | Topical antiseptics and topical antibiotics | 1 | 4 | 2 | 1 | 2 | 4 | 4 | 2 | 20 | 4
5 | Systemic antibiotics | 4 | 2 | 1 | 2 | 1 | 2 | 5 | 1 | 18 | 5
| List 2. Gaps in Knowledge about [underlined: Specific Types] of Treatments for Clinically Noninfected Chronic Venous Ulcers
1 | Biological dressings containing living cells | | 4 | | 5 | 5 | | 3 | 1 | 18 | 1
2 | Compression garments | 4 | 5 | 3 | 1 | | | 1 | | 14 | 2
3 | Growth factors | | | 2 | 4 | 2 | | 2 | 3 | 13 | 3
4 | Collagen dressings for recalcitrant2 ulcers | | 2 | | 3 | | | | 5 | 10 | 4
5 | Wound cleansing agents | 5 | | | | | | 4 | | 9 | 5
6 | Debridement agents | 3 | 3 | | | | | | 2 | 8 | 6
7 | Laser ablation for superficial veins with reflux | | | | | | 4 | | 4 | 8 | 6
8 | Valvular surgery for deep veins with reflux | | | 4 | | 3 | | | | 7 | 7
9 | Ligation for incompetent perforating veins | | | 5 | | | 2 | | | 7 | 7
10 | Sclerotherapy for superficial veins with reflux | | | | | 4 | 1 | | | 5 | 8
11 | Topical antibiotic- or antiseptic-impregnated dressings for clinically noninfected CVUs | | | | | | | 5 | | 5 | 8
12 | Radio frequency ablation for superficial veins with reflux | | | | | | 5 | | | 5 | 8
13 | Alginate fiber dressings for exudative ulcers | 1 | | | 2 | | | | | 3 | 9
14 | Negative pressure wound therapy for edematous CVUs | 2 | 1 | | | | | | | 3 | 9
15 | Arterial/venous surgery for CVUs caused by mixed arterial and venous disease | | | | | | 3 | | | 3 | 9
16 | Adjuvant treatments (e.g., pentoxiphylline) for all types of CVUs | | | 1 | | 1 | | | | 2 | 10
17 | Hydrogels and hydrocolloid dressings for dry ulcers | | | | | | | | | 0 | 11
18 | Balloon angioplasty for obstructed deep veins | | | | | | | | | 0 | 11
| List 3. Gaps in [underlined: Methods for Conducting and Reporting Research] on the Treatment of Clinically Noninfected Chronic Venous Ulcers
1 | Conducting…for measuring outcomes. | 5 | 1 | 4 | 5 | | | 2 | | 17 | 1
2 | Design…for studying simultaneous combinations of treatments. | | 4 | | 3 | 3 | 5 | | | 15 | 2
3 | Design…for selecting important outcomes (primary vs. secondary) and valid measures. | | 5 | 1 | 2 | | | 5 | | 13 | 3
4 | Conducting…for analyzing data. | 4 | | 5 | 4 | | | | | 13 | 3
5 | Design…for studying sequential combinations of treatments used as wounds heal. | | 3 | | | 2 | 4 | | | 9 | 4
6 | Reporting…for describing the participating patients (and their ulcers). | 3 | | 3 | | | 3 | | | 9 | 4
7 | Conducting…for analyzing interactions between simultaneous treatments. | | | | | 4 | 1 | 1 | | 6 | 5
8 | Conducting…for allocating patients to treatment groups. | | | | | 5 | | | | 5 | 6
9 | Reporting…for including patients who were lost to followup. | 1 | | | | | | 4 | | 5 | 6
10 | Design…for selecting valid comparison groups. | | 1 | | 1 | 1 | 2 | | | 5 | 6
11 | Design…for establishing the needed duration of followup. | | | | | | | 3 | | 3
12 | Reporting…for describing all patients' flow through studies. | 2 | | | | | | | | 2
13 | Design…for estimating proper sample sizes. | | | | | | | | | 0
14 | Conducting…for recruiting patients. | | | | | | | | | 0
15 | Reporting…for reporting harms. | | | | | | | | | 0
16 | Definitions…“chronic venous ulcers” | | | | | | | | | 0