# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
EHC: Effective Health Care
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
MMP: Metalloprotease
PICOTS: Population, Intervention, Comparison, Outcome, Timing, Setting
RCT: randomized controlled trial