# Results

## Research Needs

We successfully enlisted the predetermined panel of stakeholders; however, despite multiple attempts, we were unable to recruit a stakeholder representing private insurers within the project timeline. A total of 10 stakeholders participated in the 2 sets of teleconference calls, and 9 stakeholders prioritized the list of FRN topics (the two stakeholders representing Center for Medicare and Medicaid Services jointly prioritized the final list of FRN topics; see Table 4).

Table 4 List of participating stakeholders

Category | Subcategory | No. of Stakeholders Who Prioritized the Final List of FRN topics
Patients and the public | NKF Patient & Family Council | 2
Providers | Clinicians – Nephrologist | 3
Providers | Clinical Chemist (Nominator) | 3
Providers | Allied Health - Dietician | 3
Payers | Private Insurer (0 participated)^*^ | 1
Payers | CMS (2 participated)^**^ | 1
Policy Makers | NIDDK – Division of Kidney, Urologic & Hematologic Diseases | 1
Principal investigators/researchers | Clinical Researcher | 2
TOTAL | | 9

Abbreviations: CMS = Center for Medicare and Medicaid Services; NIDDK = National Institute of Diabetes and Digestive and Kidney Disease; NKF = National Kidney Foundation

* Invited but declined.

** There were two stakeholders representing CMS but they jointly prioritized the final list of FRN topics.

Initially, we presented 10 FRN topics based on the CER Future Research section to the stakeholder panel for discussions. With input from the stakeholder panel, seven new topics were added. Of these, four were determined to be out of the scope of the current FRN project (see Discussion). Thus, our FRN identification process led to the nomination of 17 topics (Table 5).

Table 5 Nominated topics for Future Research Needs

Topic Rank^*^ | Topic | No. of Stakeholder Votes
High-priority FRN Topics
1 | What is the best reference standard for diagnosing (absolute or functional) iron deficiency in CKD patients? | 5
2 | What is the diagnostic accuracy of newer markers of iron status as a replacement for, or an add-on to, classical lab markers in diagnosing absolute iron deficiency? | 6
3 | What is the diagnostic accuracy of newer markers of iron status as a replacement for, or an add-on to, classical lab markers in diagnosing functional iron deficiency? | 5
4 | Which is the best marker to monitor the response to therapy and repletion status? | 5
5 | What is the best biomarker to monitor iron overload as an adverse event resulting from treatment of iron deficiency? | 5
Other Nominated FRN Topics
6 | What is the impact of managing iron status based on newer laboratory biomarkers, either alone or in addition to classical laboratory biomarkers, on patient-centered outcomes? | 4
7 | How does the test performance and clinical utility of iron status vary according to treatment subgroups (i.e. nondialysis CKD, hemodialysis, and peritoneal dialysis patients)? | 3
8 | What is the impact of managing iron status based on newer laboratory biomarkers, either alone or in addition to classical laboratory biomarkers, on intermediate outcomes? | 2
9 | What is the diagnostic accuracy of newer markers of iron status as a replacement for, or an add-on to, classical lab markers for iron deficiency? | 2
10 | Does the test performance and clinical utility of markers of iron status vary in erythropoiesis-stimulating agents and iron treatment-resistant patients? | 2
11 | What are the adverse effects or harms associated with testing or with treatments guided by tests of iron status? | 2
12 | Does the test performance and clinical utility of iron status vary according to patients with different comorbidities (e.g., diabetes, hypertension)? | 2
13 | Does the test performance and clinical utility of markers of iron status vary by CKD disease stage? | 1
14 | Does the test performance and clinical utility of markers of iron status vary by patient race/ethnicity? | 1
15 | In hemodialysis patients, does the test performance and clinical utility of markers of iron status vary by method of vascular access (i.e., catheter, arterial-venous shunt)? | 0
16 | Does the test performance and clinical utility of markers of iron status vary by sex? | 0
17 | Does the test performance and clinical utility of markers of iron status vary by patient age? | 0

Abbreviation: CKD = chronic kidney disease

* Prioritized topics (1–5) are ordered logically by clinical content. Other nominated topics are listed in the order they were prioritized by the stakeholder panel.

We considered the five topics with endorsement by at least fifty percent of the nine voting stakeholders as the highest priority FRN topics. Two of the five topics are directly based on the evidence gaps identified in the CER, and the other three were nominated primarily based on the evidence gaps identified in the CER, with more refined definitions of iron deficiency and adverse outcomes.

### High-Priority Future Research Needs Topic 1

What is the best reference standard for diagnosing (absolute or functional) iron deficiency in CKD patients?

#### Background

When evaluating iron deficiency in patients with CKD, it is useful to consider two separate and distinct definitions: absolute versus functional iron deficiency. Absolute/true/overt iron deficiency refers to the depletion of iron stores and the absence of stainable iron in the bone marrow, while functional iron deficiency refers to a clinical condition where stored iron is sufficient but circulating iron is not.45 Functional iron deficiency can occur when ESA therapy stimulates red blood cell production beyond the available supply of iron necessary for hemoglobin synthesis; it can also be caused by chronic inflammation. Unlike absolute iron deficiency, the concept of functional iron deficiency does not imply depletion of iron stores. Rather, iron stores may be nearly normal, but during ESA treatment, there may be insufficient immediately available iron to optimize ESA therapy. In ESA-treated CKD patients, the “treat-to-target” or “treat-to-goal” levels of iron tests are often used to define functional iron deficiency.45

The original CER found that, currently, there is a lack of generally accepted reference standard tests for determining iron deficiency in the setting of CKD.2 In the 27 studies that were included for Key Question 2 (What reference standards are used for the diagnosis of iron deficiency in studies evaluating test performance?), studies used two distinct methods to operationalize a reference standard for assessing the diagnostic test accuracy: (1) classical laboratory biomarkers (TSAT, ferritin, or serum iron), alone or in combination with each other; and (2) a response to intravenous iron treatment. However, across studies, there are large variations in the definitions of these reference standards. Of the 15 studies that used classical markers of iron status to define “iron deficiency” as the reference standard in calculating the test accuracy of newer markers of iron status, the most commonly used definition was TSAT ≤20% and ferritin ≤100 ng/mL (7 studies), and TSAT ≤20% (7 studies). Of the 12 that used a response to IV iron treatment as the reference standard, the most commonly used definition for a response to IV iron treatment was an increase in hemoglobin concentration ≥1 g/dL after a (variable) period of IV iron treatment. It should be noted that there was no uniform regimen of IV iron in terms of dosage and iron formulation across these studies. There was also a wide range of durations of IV iron treatment across studies.

To compare the test performance among medical tests, a common reference standard is needed. When studies used different definitions of a reference standard, the results cannot be compared nor “summed up” across studies. Synthesizing information on test performance metrics, such as sensitivity, specificity, predictive values, and likelihood ratios, is often an important part of a systematic review of a medical test, and it has a dual goal: to provide summary estimates for key quantities, and to explore and explain any observed dissimilarity (heterogeneity) in the results of the examined studies. Without using the same definition of reference standard, conducting more studies on the test performance of existing or new medical test is unlikely to add meaningfully to the body of evidence and therefore impact current practice.

#### Stakeholder Discussion

This FRN topic was raised during discussions with the stakeholder panel on the issues surrounding the lack of generally accepted reference standard tests for determining iron deficiency in the setting of CKD.2 Generally, stakeholders agreed that it is important to use the same reference standard for iron deficiency in future research. Clinician stakeholders pointed out that, from a hematologist’s perspective, bone marrow iron would be considered as the “gold standard” for diagnosing (absolute) iron deficiency. In contrast, a nephrologist needs to consider a reference standard that assesses iron storage as well as its availability or adequacy (i.e., both storage and function). Clinician stakeholders suggested that future research should focus on “functional iron deficiency.” (Note: stakeholders did not provide specific definition for functional iron deficiency) However, they also mentioned that “a response to IV iron treatment” (one of the operationalized reference standards used in many existing studies, and often referred as the reference standard for functional iron deficiency in dialysis patients) may be a different research question than the reference standard for the diagnosis of iron deficiency.

Based on the stakeholders’ discussions, it appears that iron staining of a bone marrow biopsy specimen is widely regarded as the “gold standard” for the diagnosis of (absolute) iron-deficient anemia;46 however, this viewpoint is not universally accepted in the setting of CKD.2 Moreover, taking a bone marrow sample is invasive and carries the risks of infection or bleeding at the biopsy site.47 These concerns limit the use of bone marrow iron tests in clinical practice. Despite these limitations, a bone marrow biopsy remains the most accurate measure that reflects stored iron, and thus should be used to define absolute iron deficiency (also see FRN topic 2).

For diagnosing functional iron deficiency, bone marrow iron may not be useful, because it reflects stored iron but not the iron readily available for erythropoiesis in patients treated with ESAs. To date, the only accepted means of measuring functional iron deficiency in clinical practice is to evaluate the erythropoietic response to iron administration.46 The original CER found that there was no uniform regimen of IV iron in terms of dosage and iron formulation, and that there was a wide range of durations of IV iron treatment in published studies.

#### Proposed Study Designs

Existing evidence only allows indirect comparisons across studies, and cannot provide valid information on which definition of response to IV iron (or functional iron deficiency) is the “best” (or most accurate) reference standard due to large heterogeneity across study populations. Given that currently there is a lack of generally accepted reference standard for functional iron deficiency, we propose a Consensus Expert Panel to determine the “best” (or most practical) reference standard for diagnosing functional iron deficiency in CKD patients. The goal of this panel is to balance different concerns and to develop consensus across disciplines about how research should be conducted to address this high-priority FRN topic.

##### Consensus Expert Panel

###### Value of Study Design

We suggest that prior to conducting new research studies to assess other high-priority FRN topics (topics 3 through 5), an expert panel be convened to standardize the definition for functional iron deficiency and to determine which definition should be considered most suited for use as the reference standard in future research in CKD patients. Ideally, the “best” definition for functional iron deficiency would be highly correlated with patient-centered outcomes, such as mortality, morbidity, or quality of life. The panel should also assess which intermediate outcomes (e.g., ESA or iron treatment dosages) or test characteristics (e.g., test availability/accessibility, cost) are appropriate to consider in determining the ideal definition for functional iron deficiency. In addition to representatives from all stakeholder categories, this panel should specifically include authoritative bodies and major professional organizations that have relevant interests in iron deficiency, using a process similar to that employed by the Center for Disease Control and Prevention (CDC) Lipid Standardization Program (www.cdc.gov/labstandards/lsp.html).

###### Resource Use, Size, and Duration

A consensus expert panel would require relatively few resources, as it would rely on mostly volunteerism, and most of the required resources would be associated with the logistics for in-person conferences or scientific meetings.

###### Ability to Recruit

There should be little difficulty recruiting relevant stakeholders.

###### Ethical Issues

There should be no ethical issues in using an expert panel to investigate this evidence gap.

### High-Priority Future Research Needs Topic 2

What is the diagnostic accuracy of newer markers of iron status as a replacement for, or an add-on to, classical lab markers in diagnosing absolute iron deficiency?

#### Background

This FRN topic was part of Key Question 2 in the original CER. Although the CER did find studies comparing classical and newer tests for diagnosing absolute iron deficiency, the identified studies used the classical laboratory biomarkers (alone or in combination with each other) as the reference standard for iron deficiency, essentially measuring the concordance between classical and newer biomarkers of iron status. Concordance cannot tell us which test is better and which is worse—both may be equally bad or equally good for defining iron deficiency—and thus the CER was unable to provide an answer to the question.

#### Stakeholder Discussion

Much of the discussions with the stakeholder panel revolved around the issues regarding the lack of generally accepted reference standard tests for determining iron deficiency in the setting of CKD (described earlier in FRN topic 1). In brief, iron staining of a bone marrow biopsy specimen is widely regarded as the “gold standard” for the diagnosis of (absolute) iron-deficient anemia,46 but taking a bone marrow sample is invasive and carries the risks of infection or bleeding at the biopsy site. These concerns limit the use of bone marrow iron tests in clinical practice. Despite these limitations, bone marrow iron remains the most accurate measure that reflects stored iron, and thus should be used to define absolute iron deficiency. In the original CER, no study was found examining the test accuracy of new markers of iron status as a replacement for, or an add-on to, classical laboratory biomarkers against bone marrow iron as the reference standard in late-stage CKD patients.

#### Proposed Study Designs

Prospective cohort studies are the ideal study design for future research on this topic, as they allow for multiple tests to be compared all together (which may not be feasible in randomized trials), and potential biases, such as spectrum bias and review bias (i.e., interpretation of the index test or reference standard influenced by knowledge of the results of the other test), can be minimized. Prospective cohort studies should recruit consecutive CKD patients who consent to have bone marrow aspiration for histologic examination. Depletion of bone marrow iron should be used as the reference standard for absolute iron deficiency (as described earlier in the Stakeholder Discussion section). A priori subgroup analysis should include at least the following three broad groups of CKD patients to explore the effect modifications by different CKD sub-populations: (1) late-stage CKD patients who are not on dialysis; (2) dialyzed CKD patients; and (3) patients with a kidney transplant. To rule out confounding factors, complete and detailed medical histories and patient characteristics should be evaluated to rule out other causes of anemia, such as malnutrition or abnormal hemoglobins (Thalassemia). Inflammation markers should also be measured and controlled for in statistical analyses. Because both ESA and iron treatment would confound the test results, a sufficient washout period (of at least 4 weeks) would be necessary to stop ESA and iron treatment before ascertainment of the baseline test measurements.

All study patients should receive baseline test measurements including both newer and classical biomarkers of iron status, as well as any promising novel biomarkers of interest. Bone marrow aspiration should be conducted in all patients who received baseline test measurements on the same day or within few days after the baseline test measurements, and the results examined by two or more readers blinded to the results of other tests.

##### Resource Use, Size, and Duration

Cohort studies often require large samples, so it may be necessary to have multiple sites to enroll enough patients. Since it is difficult to obtain a meaningful estimate of true positive rate (i.e., true prevalence of absolute iron deficiency anemia), and sample size calculations are sensitive to the choice of true positive rate, we recommend performing a pilot study to obtain a meaningful estimate. The sample size calculation becomes more tedious to do when the same subject undergoes multiple tests, as the correlations must then be taken into account.48

##### Ability To Recruit

It is expected to be difficult to recruit sufficient number of patients, as bone marrow aspiration is painful and poses risks to patients. Using a washout period may not be feasible for some clinical settings. In this case, studies should recruit only CKD patients who did not receive ESA and iron treatment within 1 month before baseline test measurements.

##### Ethical Issues

Risks for bone marrow aspiration are significant concerns to some patients.

### High-Priority Future Research Needs Topic 3

What is the diagnostic accuracy of newer markers of iron status as a replacement for, or an add-on to, classical lab markers in diagnosing functional iron deficiency?

#### Background

This FRN topic was also part of Key Question 2 in the original CER. Based on our post-hoc observation of this body of literature, we found that current studies often used a response to IV iron treatment as the reference standard for functional iron deficiency. The most commonly used definition for a response to IV iron treatment was an increase in hemoglobin concentration ≥1 g/dL after a period of IV iron treatment. However, there was no uniform regimen of IV iron in terms of dosage and iron formulation. There was also a wide range of durations of IV iron treatment across studies. The potential impacts of IV iron treatment regimen on the test performance of newer or classical laboratory markers of iron status are not known.

The CER also found that, in adult hemodialysis CKD patients, CHr had a similar or better overall test accuracy compared with classical markers (TSAT or ferritin) to predict a response to IV iron treatment. Data suggested that CHr (with cutoff values of <27 or <28 pg) had a better sensitivity and specificity to predict a response to IV iron treatment than classical markers (TSAT <20 or ferritin <100 ng/mL). The %HYPO of red blood cells had a similar or better overall test accuracy compared with TSAT, and better overall test accuracy compared with ferritin, to predict a response to IV iron treatment. Data also suggested that %HYPO (with cutoff values of >6% or >10%) had a better sensitivity and specificity to predict a response to IV iron treatment than classical markers (TSAT <20% or ferritin <100 ng/mL). sTfR had a similar test performance compared with classical markers (TSAT or ferritin) to predict a response to IV iron treatment.

There is insufficient evidence regarding test performance of newer markers of iron status as an add-on to older markers, and test performance comparing newer with classical laboratory markers to predict a response to IV iron treatment in adult PD and nondialysis CKD patients, and in pediatric CKD patients.

#### Stakeholder Discussion

Much of the discussions with the stakeholder panel revolved around issues regarding the lack of generally accepted reference standard tests for determining iron deficiency in the setting of CKD (described earlier in FRN topic 1). In brief, stakeholders agreed that it is important to use the same reference standard for iron deficiency in future research; however, it appears that there is currently no consensus on whether “a response to IV iron treatment” should be considered as “functional iron deficiency” and that currently there is a lack of a well-accepted definition for a response to IV iron treatment. Stakeholders’ comments were consistent with what we observed from the published research on this topic.

#### Proposed Study Designs

Unlike FRN topic 2 (diagnosing absolute deficiency), this topic cannot go forward until a reference standard for functional iron deficiency has been established. We therefore propose a Consensus Expert Panel to first determine the “best” (or most practical) reference standard for diagnosing functional iron deficiency in CKD patients (described in the FRN topic 1 in detail). Future research on this topic should use the same reference standard, in order to build on the body of evidence on this important research question and allow systematic review and meta-analysis to compare results across studies. If the reference standard for “functional iron deficiency” is defined by a response to ESA or iron treatment, a standardized protocol to ascertain the treatment response must be established, including the dosage and ESA and/or iron formulation and the followup duration to detect a response. There should be no change in patients’ care to minimize the confounding, and the treatment response should be significantly different from biological variability in stable CKD patients.

Prospective cohort studies with consecutive CKD patients are the ideal study design for future research on this topic, as multiple tests can be compared all together (which may not be feasible in randomized trials), and potential biases, such as spectrum bias and review bias (i.e., interpretation of the index test or reference standard influenced by knowledge of the results of the other test), can be minimized. The agreed upon definition by the consensus expert panel should be used as the reference standard for diagnosing functional iron deficiency. A priori subgroup analysis should include at least the following three broad groups of CKD patients to explore the effect modifications by different CKD sub-populations: (1) late stage CKD patients who are not on dialysis; (2) dialyzed CKD patients; and (3) patients with a kidney transplant. To rule out confounding factors, complete and detailed medical histories and patient characteristics should be evaluated to rule out other causes of anemia, such as malnutrition or abnormal hemoglobins (Thalassemia). Inflammation markers should also be measured and controlled for in the statistical analyses. If the reference standard for functional iron deficiency is defined by a response to ESA or iron treatment, a sufficient washout period (of at least 4 weeks) is necessary to stop ESA and iron treatment before ascertainment of baseline test measurements.

All study patients should receive baseline test measurements including both newer and classical biomarkers of iron status, as well as any promising novel biomarkers of interest. Tests for assessing functional iron deficiency should be conducted in all patients who received baseline test measurements, and should be examined by two or more readers blinded to the results of other tests. If the reference standard for functional iron deficiency is defined by a response to ESA or iron treatment, newly conducted studies should adhere to the standardized protocol to ascertain the treatment response.

##### Resource Use, Size, and Duration

Cohort studies often require larger samples, so it may be necessary to have multiple sites to enroll enough patients. Since it is difficult to obtain a meaningful estimate of the true positive rate (i.e., the true prevalence of functional iron deficiency anemia) and sample size calculations are sensitive to the choice of true positive rate, we recommend performing a pilot study to obtain a meaningful estimate. The sample size calculation becomes more tedious when the same subject undergoes multiple tests, as the correlations must then be taken into account.48

##### Ability to Recruit

It should be relatively easy to recruit patients into a prospective cohort study. The major burden would be additional testing as per protocol. The reliance on observational data substantially reduces resource use and increases the feasibility of addressing this evidence gap. Using a washout period may not be feasible for some clinical settings. In this case, studies should recruit only CKD patients who did not receive ESA and iron treatment within 1 month before baseline test measurements.

##### Ethical Issues

There should be no ethical concerns for observational studies.

### High-Priority Future Research Needs Topic 4

Which is the best marker to monitor the response to therapy and repletion status?

#### Background

The original CER did not directly address this FRN topic; however, this topic is closely related to FRN topic 3 (diagnosing functional iron deficiency). Since functional iron deficiency can be defined by a response to ESA or iron treatment, it is possible that this FRN topic is the same as FRN topic 3, although the purpose of the iron biomarkers is to monitor for iron deficiency anemia during treatment, not for diagnosing functional iron deficiency. It is important to note that studies included in Key Question 2 of the CER (diagnostic accuracy of newer markers of iron status as a replacement for, or an add-on to, classical lab markers in diagnosing functional iron deficiency) often did not explicitly state that the use of newer or classical lab markers was to diagnose functional iron deficiency. In fact, several studies that were included in the Key Question 2 of CER aimed to examine the test accuracy of iron biomarkers to “predict a response to treatment.” Typically, “treat-to-target” or “treat-to-goal” levels of iron tests were used to monitor repletion status. It appears that there is a great deal of confusion/uncertainty in both the definition of functional iron deficiency and the purpose for iron status testing in existing research comparing the test performance of newer markers of iron status with that of classical markers.

Since monitoring tests are used repeatedly (usually in a given schedule) and more frequently than diagnostic tests, it would be sensible to use tests that have only a small diurnal variation so that real changes can be reflected accurately.

#### Stakeholder Discussion

The topic was nominated, based on stakeholder discussion and feedback, in the context of the “continuum of decision points in clinical management where biomarkers could be useful, but evidence is needed.” In addition to diagnostic accuracy and safety, stakeholder discussion of the topic included additional characteristics of ideal biomarkers such as cost and availability. As with other high-priority FRN topics, establishing a reference standard was identified by stakeholders as necessary to assess test performance among relevant biomarkers.

#### Proposed Study Designs

Although the FRN topic poses a simple, noncomparative question, it is unclear which biomarkers and outcomes are most appropriate and relevant to study. Other potential biomarkers beyond the biomarkers of interest of the CER may be considered in future research. In the study design section below, we initially propose a Consensus Expert Panel with Horizon Scan to further specify the potentially limitless list of biomarkers and relevant outcomes (i.e., which outcomes determine which biomarker is the “best”).

##### Consensus Expert Panel With Horizon Scan

###### Value of Study Design

We suggest that as a first step, prior to conducting new research studies to assess the best biomarker to monitor the response to therapy and repletion status, an expert panel should be convened to determine which markers appear most promising to explore in future research. Markers that can separate cell hemoglobinization from cell production would have a better chance of elucidating the underlying mechanism, and should the mechanism in question eventually become the treatment target, the anemia might as a consequence be more appropriately managed. Markers that have a specificity to the responses related to ESA or iron delivery would be optimal. The panel should assess which outcomes (e.g., specificity, sensitivity, adverse events) and test characteristics (e.g., test availability/accessibility, cost) are appropriate to consider in determining an ideal marker to monitor response to therapy and repletion status.

A Horizon Scan—a cursory summary of topic-relevant studies found using a systematic literature search—should be conducted to inform panel decisionmaking. The Horizon Scan could also be used to help assess the appropriateness of a CER on this topic. In addition to representatives from the current stakeholder categories, this panel should specifically include clinical chemists and hematologists. The main drawback to this approach would be that stakeholder opinion rather than evidence may well dictate the choice of biomarkers to study. However, given the resources that would be required to investigate all possible biomarkers, this tradeoff is likely to be reasonable.

Following identification of the most appropriate biomarkers by the expert panel, and determination of a reference standard, prospective cohort studies with consecutive CKD patients would pose the ideal study design for future research on this topic. We propose the same study design considerations as FRN topic 3, with the exception of study outcomes. Instead of test performance outcomes, future research on this topic should assess clinical or patient-centered outcomes.

###### Resource Use, Size, and Duration

Initially, using an expert panel to identify promising biomarkers for future study would be more efficient than large studies assessing many different types/combinations of biomarkers, which would consume a large amount of resources. Expertise in literature search, assessment, and data extraction would be necessary to conduct the accompanying horizon scan.

###### Ability To Recruit

There should be little difficulty recruiting relevant stakeholders for the expert panel.

###### Ethical Issues

There should be no ethical issues in using an expert panel and horizon scan to investigate this evidence gap.

### High-Priority Future Research Needs Topic 5

What is the best biomarker to monitor iron overload as an adverse event resulting from treatment of iron deficiency?

#### Background

Iron overload increases the risk for liver disease (cirrhosis, cancer), heart attack or heart failure, diabetes mellitus, osteoarthritis, osteoporosis, metabolic syndrome, hypothyroidism, hypogonadism, numerous undesirable symptoms, and in some cases premature death.

The original CER looked for evidence of the adverse effects or harms associated with the treatments guided by tests of iron status. However, it found insufficient evidence for this question.

#### Stakeholder Discussion

This topic was brought up during stakeholder discussion regarding the change in current dialysis practice, that is, decreasing ESA dosing while increasing iron treatment to reach the target hemoglobin level. The stakeholders stated that the increase in iron treatment will be accompanied by an increased risk of iron overload. In the opinions of the stakeholders, there are currently no reliable markers for monitoring iron overload.

#### Proposed Study Designs

Although the FRN topic poses a simple, non-comparative question, it is unclear which biomarkers are most appropriate and relevant for study. Other potential biomarkers beyond the biomarkers of interest in the CER may be considered in future research. In the study design section below, we initially propose a Consensus Expert Panel with Horizon Scan to further circumscribe the potentially limitless list of biomarkers.

##### Consensus Expert Panel With Horizon Scan

###### Value of Study Design

We suggest that as a first step, prior to conducting new research studies to assess the best biomarker to monitor iron overload as an adverse event, an expert panel should be convened to determine which markers appear most promising to explore in future research. Ideal markers would be significantly associated with clinically important outcomes. Horizon Scan could also be used to help assess the appropriateness of a systematic review on the associations between the markers of interest and clinically important outcomes.

###### Resource Use, Size, and Duration

Initially, using an expert panel to identify promising biomarkers for future study would be more efficient than large studies assessing many different types/combinations of biomarkers, which would consume a large amount of resources. Expertise in literature search, assessment, and data extraction would be necessary to conduct the accompanying horizon scan.

###### Ability To Recruit

There should be little difficulty recruiting relevant stakeholders for the expert panel.

###### Ethical Issues

There should be no ethical issues in using an expert panel and horizon scan to investigate this evidence gap.