# References

1 KDOQI Clinical Practice Guidelines and Clinical Practice Recommendations for Anemia in Chronic Kidney Disease. Am J Kidney Dis. May. 2006;47(5 Suppl 3):S11-145. [pmid: 16678659].
2 Anaemia Management in Chronic Kidney Disease - Rapid Update 2011. National Clinical Guideline Centre. 2011. www.ncbi.nlm.nih.gov/books/NBK65530/pdf/TOC.pdf.
3 Winkel P, Statland BE, Bokelund H. Factors contributing to intra-individual variation of serum constituents: 5. Short-term day-to-day and within-hour variation of serum constituents in healthy subjects. Clin Chem. Dec. 1974;20(12):1520-27. [pmid: 4430129].
4 Winkel P, Statland BE, Bokelund H. The effects of time of venipuncture on variation of serum constituents. Consideration of within-day and day-to-day changes in a group of healthy young men. Am J Clin Pathol. Oct. 1975;64(4):433-47. [pmid: 1239188].
5 Wish JB. Assessing iron status: beyond serum ferritin and transferrin saturation. Clin J Am Soc Nephrol. Sep. Suppl 1. 2006;1:S4-S8. [pmid: 17699374].
6 Guyatt GH, Oxman AD, Ali M, et al. Laboratory diagnosis of iron-deficiency anemia: an overview. J Gen Intern Med. Mar. 1992;7(2):145-53. [pmid: 1487761].
7 Brugnara C, Schiller B, Moran J. Reticulocyte hemoglobin equivalent (Ret He) and assessment of iron-deficient states. Clinical & Laboratory Haematology. Oct. 2006;28(5):303-08. [pmid: 16999719].
8 Braun J, Lindner K, Schreiber M, et al. Percentage of hypochromic red blood cells as predictor of erythropoietic and iron response after i.v. iron supplementation in maintenance haemodialysis patients. Nephrol Dial Transplant. Jun. 1997;12(6):1173-81. [pmid: 9198047].
9 Macdougall IC, Cavill I, Hulme B, et al. Detection of functional iron deficiency during erythropoietin treatment: a new approach. BMJ. Jan. 25. 1992;304(6821):225-26. [pmid: 1739797].
10 Braun J. Erythrocyte zinc protoporphyrin. Kidney Int Suppl. Mar. 1999;69:S57-S60. [pmid: 10084287].
11 Babitt JL, Lin HY. Molecular mechanisms of hepcidin regulation: implications for the anemia of CKD. Am J Kidney Dis. Apr. 2010;55(4):726-41. [pmid: 20189278].
12 Gandon Y, Olivie D, Guyader D, et al. Non-invasive assessment of hepatic iron stores by MRI. Lancet. Jan. 31. 2004;363(9406):357-62. [pmid: 15070565].
13 IV. NKF-K/DOQI Clinical Practice Guidelines for Anemia of Chronic Kidney Disease: update 2000. Am J Kidney Dis. Jan. 2001;37(1 Suppl 1):S182-S238. [pmid: 11229970].
14 Chung M, Moorthy D, Hadar N, et al. Biomarkers for Assessing and Managing Iron Deficiency Anemia in Late-Stage Chronic Kidney Disease. Comparative Effectiveness Review No. 83. (Prepared by the Tufts Evidence-based Practice Center under Contract No. 290-2007-10055-I.) AHRQ Publication No. 12(13)-EHC140-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
15 Baldus M, Walter H, Thies K, et al. Transferrin receptor assay and zinc protoporphyrin as markers of iron-deficient erythropoiesis in end-stage renal disease patients. Clinical Nephrology. Mar. 1998;49(3):186-92. [pmid: 9543601].
16 Bhandari S, Norfolk D, Brownjohn A, et al. Evaluation of RBC ferritin and reticulocyte measurements in monitoring response to intravenous iron therapy. American Journal of Kidney Diseases. Dec. 1997;30(6):814-21. [pmid: 9398126].
17 Bhandari S, Turney JH, Brownjohn AM, et al. Reticulocyte indices in patients with end stage renal disease on hemodialysis. Journal of Nephrology. Mar. 1998;11(2):78-82. [pmid: 9589378].
18 Bovy C, Gothot A, Delanaye P, et al. Mature erythrocyte parameters as new markers of functional iron deficiency in haemodialysis: sensitivity and specificity. Nephrology Dialysis Transplantation. Apr. 2007;22(4):1156-62. [pmid: 17237481].
19 Buttarello M, Pajola R, Novello E, et al. Diagnosis of iron deficiency in patients undergoing hemodialysis. American Journal of Clinical Pathology. Jun. 2010;133(6):949-54. [pmid: 20472854].
20 Chuang CL, Liu RS, Wei YH, et al. Early prediction of response to intravenous iron supplementation by reticulocyte haemoglobin content and high-fluorescence reticulocyte count in haemodialysis patients. Nephrology Dialysis Transplantation. Feb. 2003;18(2):370-77. [pmid: 12543894].
21 Cullen P, Soffker J, Hopfl M, et al. Hypochromic red cells and reticulocyte haemglobin content as markers of iron-deficient erythropoiesis in patients undergoing chronic haemodialysis. Nephrology Dialysis Transplantation. Mar. 1999;14(3):659-65. [pmid: 10193816].
22 Daschner M, Mehls O, Schaefer F. Soluble transferrin receptor is correlated with erythropoietin sensitivity in dialysis patients. Clinical Nephrology. Oct. 1999;52(4):246-52. [pmid: 10543327].
23 Domrongkitchaiporn S, Jirakranont B, Atamasrikul K, et al. Indices of iron status in continuous ambulatory peritoneal dialysis patients. American Journal of Kidney Diseases. Jul. 1999;34(1):29-35. [pmid: 10401012].
24 Eguchi A, Tsuchiya K, Tsukada M, et al. Clinical usefulness of reticulocyte hemoglobin equivalent (RET-He) in patients at the pre-dialysis stage and in patients on peritoneal dialysis. [Japanese]. Nippon Jinzo Gakkai Shi. Japanese. 2010;(2):132-40. [pmid: 20415234].
25 Fishbane S, Galgano C, Langley RC Jr, et al. Reticulocyte hemoglobin content in the evaluation of iron status of hemodialysis patients. Kidney International. Jul. 1997;52(1):217-22. [pmid: 9211366].
26 Fusaro M, Munaretto G, Spinello M, et al. Soluble transferrin receptors and reticulocyte hemoglobin concentration in the assessment of iron deficiency in hemodialysis patients. Journal of Nephrology. Jan. 2005;18(1):72-79. [pmid: 15772926].
27 Gupta M, Kannan M, Gupta S, et al. Contribution of iron deficiency to anemia in chronic renal failure. Indian Journal of Pathology & Microbiology. Oct. 2003;46(4):563-64. [pmid: 15025343].
28 Hukic F, Nuhbegovic S, Brkic S, et al. Biochemical markers of iron status in hemodialysis patients. Medicinski Arhiv. 2010;64(4):219-22. [pmid: 21246919].
29 Kim JM, Ihm CH, Kim HJ. Evaluation of reticulocyte haemoglobin content as marker of iron deficiency and predictor of response to intravenous iron in haemodialysis patients. International Journal of Laboratory Hematology. Feb. 2008;30(1):46-52. [pmid: 18190467].
30 Matuszkiewicz-Rowinska J, Ostrowski G, Niemczyk S, et al. Red cell zinc protoporphyrin and its ratio to serum ferritin (ZPP/logSF index) in the detection of iron deficiency in patients with end-stage renal failure on hemodialysis. [Polish]. Polskie Archiwum Medycyny Wewnetrznej. Jul. 2003;110(1):703-10. [pmid: 14682204].
31 Mitsuiki K, Harada A, Miyata Y. Assessment of iron deficiency in chronic hemodialysis patients: investigation of cutoff values for reticulocyte hemoglobin content. Clinical & Experimental Nephrology. Mar. 2003;7(1):52-57. [pmid: 14586744].
32 Mittman N, Sreedhara R, Mushnick R, et al. Reticulocyte hemoglobin content predicts functional iron deficiency in hemodialysis patients receiving rHuEPO. American Journal of Kidney Diseases. Dec. 1997;30(6):912-22. [pmid: 9398141].
33 Miwa N, Akiba T, Kimata N, et al. Usefulness of measuring reticulocyte hemoglobin equivalent in the management of haemodialysis patients with iron deficiency. International Journal of Laboratory Hematology. Apr. 2010;32(2):248-55. [pmid: 19624802].
34 Tessitore N, Solero GP, Lippi G, et al. The role of iron status markers in predicting response to intravenous iron in haemodialysis patients on maintenance erythropoietin. Nephrology Dialysis Transplantation. Jul. 2001;16(7):1416-23. [pmid: 11427634].
35 Tessitore N, Girelli D, Campostrini N, et al. Hepcidin is not useful as a biomarker for iron needs in haemodialysis patients on maintenance erythropoiesis-stimulating agents. Nephrology Dialysis Transplantation. Dec. 2010;25(12):3996-4002. [pmid: 20538788].
36 Tsuchiya K, Okano H, Teramura M, et al. Content of reticulocyte hemoglobin is a reliable tool for determining iron deficiency in dialysis patients. Clinical Nephrology. Feb. 2003;59(2):115-23. [pmid: 12608554].
37 Van Wyck DB, Roppolo M, Martinez CO, et al. A randomized, controlled trial comparing IV iron sucrose to oral iron in anemic patients with nondialysis-dependent CKD. Kidney International. Dec. 2005;68(6):2846-56. [pmid: 16316362].
38 Fishbane S, Lynn RI. The utility of zinc protoporphyrin for predicting the need for intravenous iron therapy in hemodialysis patients. American Journal of Kidney Diseases. Mar. 1995;25(3):426-32. [pmid: 7872320].
39 Kaneko Y, Miyazaki S, Hirasawa Y, et al. Transferrin saturation versus reticulocyte hemoglobin content for iron deficiency in Japanese hemodialysis patients. Kidney International. Mar. 2003;63(3):1086-93. [pmid: 12631092].
40 Silva J, Andrade S, Ventura H, et al. Iron supplementation in haemodialysis--practical clinical guidelines. Nephrology Dialysis Transplantation. Oct. 1998;13(10):2572-77. [pmid: 9794562].
41 Fishbane S, Shapiro W, Dutka P, et al. A randomized trial of iron deficiency testing strategies in hemodialysis patients. Kidney International. Dec. 2001;60(6):2406-11. [pmid: 11737617].
42 Singh AK, Coyne DW, Shapiro W, et al. Predictors of the response to treatment in anemic hemodialysis patients with high serum ferritin and low transferrin saturation. Kidney International. Jun. 2007;71(11):1163-71. [pmid: 17396118].
43 Ahluwalia N, Skikne BS, Savin V, et al. Markers of masked iron deficiency and effectiveness of EPO therapy in chronic renal failure. American Journal of Kidney Diseases. Oct. 1997;30(4):532-41. [pmid: 9328369].
44 Concannon TW, Meissner P, Grunbaum JA, et al. A new taxonomy for stakeholder engagement in patient-centered outcomes research. J Gen Intern Med. Aug. 2012;27(8):985-91. [pmid: 22528615].
45 Fishbane S. Iron management in nondialysis-dependent CKD. Am J Kidney Dis. Jun. 2007;49(6):736-43. [pmid: 17533016].
46 Hung SC, Tarng DC. Bone marrow iron in CKD: correlation with functional iron deficiency. Am J Kidney Dis. Apr. 2010;55(4):617-21. [pmid: 20338462].
47 Bain BJ. Bone marrow biopsy morbidity: review of 2003. J Clin Pathol. Apr. 2005;58(4):406-08. [pmid: 15790706].
48 Liu A, Schisterman EF, Mazumdar M, et al. Power and sample size calculation of comparative diagnostic accuracy studies with multiple correlated test results. Biom J. Apr. 2005;47(2):140-50. [pmid: 16389911].