# Executive Summary

## Background

Anemia is a common complication of chronic kidney disease (CKD). The management of anemia in CKD patients must strike an appropriate balance between stimulating generation of erythroblasts (erythropoiesis) and maintaining sufficient iron levels for optimum hemoglobin (Hb) production.1 As such, it is important to assess iron stores and the availability of iron for erythropoiesis, as adequate iron status is integral to both iron and anemia managements in CKD patients.

Classical iron status tests, of which ferritin and transferrin saturation (TSAT) are the most widely used, exhibit large biological variability in the context of underlying inflammation of CKD.2–4 The accurate assessment of iron status is dependent on the validity and reliability of laboratory test results, and differences in test performance pose a dilemma regarding the most appropriate test to guide treatment decisions. Several novel biomarkers of iron status have been proposed as alternatives to the classical iron status tests. These include hemoglobin content of reticulocytes (CHr), reticulocyte hemoglobin equivalent (RetHe), percentage of hypochromic erythrocytes (%HYPO), erythrocyte zinc protoporphyrin (ZPP), soluble transferrin receptor (sTfR), and hepcidin. In addition, Superconducting Quantum Interference Devices (SQUIDs) are an alternative non-invasive means for detecting and quantifying liver iron content, via the paramagnetic properties of iron (magnetic resonance diminishes in the liver as iron concentration increases).

The Tufts Evidence-based Practice Center (EPC) conducted a Comparative Effectiveness Review (CER) to systematically evaluate studies that examined the impact on patient-centered outcomes of using the newer laboratory biomarkers as a replacement for or as an add-on to classical laboratory biomarkers of iron status for assessing iron status and the management of iron deficiency in adult and pediatric CKD patients (nondialysis and dialysis).5 The Key Questions for the CER are presented below:

### Key Question 1 (Overarching Question)

What is the impact on patient centered outcomes of using the newer^a^ laboratory biomarkers as a replacement for or an add-on to the older (classical) laboratory biomarkers of iron status^b^ for assessing iron status and management of iron deficiency in stages 3–5 CKD patients (nondialysis and dialysis), and in patients with a kidney transplant?

a Newer laboratory biomarkers: content of Hb in reticulocytes, percentage of hypochromic red blood cells, erythrocyte zinc protoporphyrin, soluble transferrin receptor, hepcidin, and superconducting quantum interference devices.

b Older laboratory biomarkers: bone marrow iron stores, serum iron, transferrin saturation, iron-binding capacity, and ferritin.

### Key Question 2

What is the test performance of newer markers of iron status as a replacement for or an add-on to the older markers in stages 3–5 CKD patients nondialysis and dialysis, and in patients with a kidney transplant?

a. What reference standards are used for the diagnosis of iron status in studies evaluating test performance?
b. What are the adverse effects or harms associated with testing using newer and/or older markers of iron status?

### Key Question 3

In stages 3–5 nondialysis and dialysis CKD patients with iron deficiency, what is the impact of managing iron status based on newer laboratory biomarkers either alone or in addition to older laboratory biomarkers on intermediate outcomes (e.g., improvement in Hb levels, dose of erythropoiesis-stimulating agents, time in target Hb range), compared with managing iron status based on older laboratory biomarkers alone?

a. What are the adverse effects or harms associated with the treatments guided by tests of iron status?

### Key Question 4

What factors affect the test performance and clinical utility of newer markers of iron status, either alone or in addition to older laboratory biomarkers, in stages 3–5 (nondialysis and dialysis) CKD patients with iron deficiency?

Combining the evidence addressing Key Questions 2, 3, and 4, the CER concluded that there is currently insufficient data to determine if most newer laboratory biomarkers of iron status are better than classical markers for predicting iron deficiency as defined by a response to an iron challenge test. However, it may be that CHr and %HYPO have better predictive ability for a response to intravenous (IV) iron treatment than classical markers (TSAT <20% or ferritin <100 ng/mL) in HD CKD patients. In addition, results from two randomized controlled trials (RCTs) showed a reduction in the number of iron status tests and resulting IV iron treatments administered to patients whose iron management was guided by CHr, compared with those guided by TSAT or ferritin. These results suggest that CHr may reduce potential harms from IV iron treatment by lowering the frequency of iron testing; however, the evidence for the potential harms associated with testing or test-associated treatment is insufficient.

Nevertheless, the strength of evidence supporting these conclusions is low and there remains considerable clinical uncertainty regarding the use of newer markers in the assessment of iron status and the management of iron deficiency in stages 3–5 CKD patients (both nondialysis and dialysis). In addition, factors that may affect the test performance and clinical utility of newer laboratory markers of iron status remain largely unexamined.

Table A summarizes the evidence gaps identified in the CER. One major evidence gap concerns the dearth of pediatric studies. Addressing this gap would require a specially-composed stakeholder group for determining specific Future Research Needs (FRN). For this reason, the current FRN project is focused on adult CKD patients (nondialysis and dialysis).

Table A Research gaps and suggestions for future research

Key Questions | Research Gaps
Key Question 1 (overarching question). What is the impact on patient centered outcomes of using the newer laboratory biomarkers^a^ as a replacement for or an add-on to the older laboratory biomarkers of iron status for assessing iron status and management of iron deficiency? | No studies were found that provided data directly addressing our overarching question regarding the impact of using newer laboratory biomarkers on patient-centered outcomes (e.g., mortality, morbidity, quality of life, and adverse effects). All gaps described in Key Questions 2, 3, and 4 are applicable to this overarching question.
Key Question 2. What is the diagnostic test accuracy of newer markers of iron status as a replacement for or an add-on to classical laboratory markers? 2a. What reference standards are used for the diagnosis of iron status in studies evaluating test accuracy? 2b. What are the adverse effects or harms associated with testing using newer and/or older markers of iron status? | Populations:; - Insufficient evidence in adult PD CKD and ND CKD patients.; - Whether test performance and clinical utility of newer or classical markers of iron status vary by different CKD populations is unknown.; Interventions and comparators:; - Insufficient evidence for the test performance of newer markers of iron status as an add-on to older markers.; Outcomes:; - There is a lack of a generally accepted reference standard test for determining iron deficiency in the setting of CKD.1; - A small percentage (26%) of the identified studies reported information on harms, and most studies did not attribute harms to either testing or treatment.; Study Design Issues:; - Many existing studies are at a high risk of bias due to lack of demographic details of study populations and blinding of the diagnosis or patient characteristics. These biases limit studies’ utility in informing clinical practice.; - Existing studies were underpowered, leading to imprecise estimates.
Key Question 3. What is the impact of managing iron status based on newer laboratory biomarkers either alone or in addition to older laboratory biomarkers on intermediate outcomes? 3a. What are the adverse effects or harms associated with the treatments guided by tests of iron status? | Populations:; - Insufficient evidence in adult PD CKD and ND CKD patients.; Interventions and comparators:; - There are no uniform iron management algorithms or test-and-treat protocols across studies.; - There are a lack of studies with longer followup durations; existing short-term RCTs had a followup duration less than 6 months.; - No study compared iron management guided by classical markers with that of newer markers (%HYPO, sTfR, RetHe, ZPP, or hepcidin), except for CHr.; Outcomes:; - The two RCTs showed different findings regarding the dose of epoetin required to maintain the Hct target as the primary outcome, possibly due to differences in the Hct targets (an indication for the adequacy of anemia management). Thus, the findings from the two RCTs could not be combined together. Important intermediate outcomes suggested by the experts include:; ○ Increase in Hb or hematocrit, or more consistent maintenance of Hb or hematocrit within the desired range; ○ Use of ESA for maintenance of Hb within the desired range (stable dose in contrast to escalating dose resulting in net decreased ESA dose in hyporesponsive patients or actual decreased ESA dose in relatively responsive patients); ○ Adverse effects or harms associated with different management strategies
Key Question 4. What factors affect the test performance and clinical utility of newer markers of iron status? | - Insufficient evidence to draw conclusions regarding factors that may affect the test performance or clinical utility of laboratory markers of iron status. Important factors suggested by the experts include:; ○ Biological variation in diagnostic indices; ○ Use of different diagnostic reference standards; ○ Type of dialysis (i.e., peritoneal or hemodialysis); ○ Patient subgroups (i.e., age, sex, comorbid conditions, erythropoiesis-stimulating agent resistance, protein energy malnutrition secondary to an inflammatory state, hemoglobinopathies [e.g., thalessemia and sickle cell anemia]); ○ Route of iron administration (i.e., oral or intravenous); ○ Treatment regimen (i.e., repletion or continuous treatment); ○ Interactions between treatments (i.e., patients treated with vs. without ESA, patients treated with vs. without iron-replacement therapy); - All gaps described in Key Questions 2 and 3 are also applicable here.

Abbreviations: CHr = Hb content of reticulocytes; CKD = chronic kidney disease; ESA = erythropoiesis-stimulating agent; HB = hemoglobin; Hct = hematocrit; %HYPO = percentage of hypochromic erythrocytes; ND = nondialysis; PD = peritoneal dialysis; RCT = randomized controlled trial; RetHe = Reticulocyte hemoglobin equivalent; sTfR = soluble transferrin receptor; TSAT = transferrin saturation; ZPP = erythrocyte zinc protoporphyrin

## Methods

### Identification of Evidence Gaps

As the original authors of the CER, we generated the initial list of FRN topics based on the Research Needs section of the report, and then organized the list of evidence gaps by Key Question and PICOD ([underlined: P]opulation, [underlined: I]ntervention, [underlined: C]omparator, [underlined: O]utcomes, and study [underlined: D]esign) element. We then used an iterative process to identify additional FRN topics through Webinars and email correspondence with a stakeholder panel. The nominated topics were evaluated by EPC program staff to determine whether the nominated topics were related to one of the Key Questions of the CER or not. In general, nominated topics were deemed out-of-scope if the state of the evidence was not rigorously assessed as part of the CER. These out-of-scope topics were not entered to the final list of potential topics, but were rather enumerated in the Discussion of this report. We asked the stakeholder panel to prioritize the FRN topics following a formalized schema of prioritization criteria.

### Criteria for Prioritization

Stakeholders (described in the next section) were asked to consider four dimensions of need as outlined in the Effective Health Care Program Selection Criteria: Importance, Desirability of Research/Avoidance of Unnecessary Duplication, Feasibility, and Potential Impact.

### Engagement of Stakeholders, Researchers, and Funders

To form the Stakeholder panel, we adapted a Tufts-developed “7Ps” model of stakeholder engagement,6 which identifies seven primary stakeholder categories: Patients and the Public, Providers, Purchasers, Payers, Policymakers, Principal investigators, and Product makers. These categories are not necessarily mutually exclusive, and one stakeholder may belong to more than one category. For this study, product makers and purchasers were not included. Stakeholders were contacted by email with a brief description of the project and its purpose, a formal invitation to serve as a stakeholder, and the executive summary of the original CER. Once their participation was confirmed, we sent additional materials to orient stakeholders including the Future Research Needs section of the original CER and a proposed outline for this project.

The first round of Webinars was held in June 2012. In these Webinars, we reviewed the purpose and processes of this project. We then reviewed the research gaps identified in the CER, and explained the criteria for prioritization. After this orientation, the stakeholders were asked to identify additional FRN topics of interest to them and to discuss their or others’ suggested topics, the supporting rationale, or related research challenges. Topics nominated by stakeholders were incorporated into the topic list along with their supporting rationale, which we condensed from the discussion and subsequent emails. We combined duplicate or similar FRN topics together and disseminated the revised list of topics, along with minutes from all the Webinars, with an invitation to comment on the nominated topics and supporting rationales.

We held the second round of Webinars in late June and early July of 2012, during which we reviewed the refined list of nominated topics. Stakeholders were asked if their nominations were appropriately captured and accounted for, and were provided the opportunity to participate in further discussion.

Following this second round, we further edited the topic list based on stakeholder rationale. The finalized topic prioritization form and the minutes from the second set of webinars were sent to each stakeholder. Stakeholders were asked to review the minutes for accuracy and in order to hear the perspectives of others, and then to identify their top five priority topics along with corresponding justification for each topic based upon the Agency for Healthcare Research and Quality’s (AHRQ’s) Effective Health Care Program Selection Criteria. The five topics with the highest number of stakeholder endorsements were designated as the prioritized FRN.

### Research Question Development and Research Design Considerations

We transformed the final list of FRN topics into research questions using standard PICOD criteria. (Stakeholders were not utilized during this process.) We discussed various alternatives for future research efforts aimed at answering each question, specifically considering the feasibility of addressing the potential research questions with respect to sample size, the time required, recruitment, and possible ethical concerns. In particular, we evaluated the advantages and disadvantages of various potential research designs with regards to:

## Results

Based on the CER’s Future Research section and our discussion with stakeholders, 17 Future Research Needs topics were nominated. We considered the five topics with endorsement by at least fifty percent of the nine voting stakeholders as the highest priority FRN topics. The topics chosen as the highest priority Future Research Needs are listed in Table B.

Table B Top five Future Research Needs as indicated by participating stakeholders^*^

Topic | Topic Description
1 | What is the best reference standard for diagnosing (absolute or functional) iron deficiency in CKD patients?
2 | What is the diagnostic accuracy of newer markers of iron status as a replacement for, or an add-on to, classical lab markers in diagnosing absolute iron deficiency?
3 | What is the diagnostic accuracy of newer markers of iron status as a replacement for, or an add-on to, classical lab markers in diagnosing functional iron deficiency?
4 | Which is the best marker to monitor the response to therapy and repletion status?
5 | What is the best biomarker to monitor iron overload as an adverse event resulting from treatment of iron deficiency?

* Prioritized topics (1–5) are ordered logically by clinical content.

Nomination of FRN Topic 1 highlights the current lack of a well-accepted reference standard for diagnosing iron deficiency in CKD patients, which is consistent with the findings of our CER. To compare the test performance among medical tests, a common reference standard is needed. When studies use different definitions of a reference standard, the results cannot be compared or “summed up” across studies. Without using the same definition of reference standard, conducting more studies on the test performance of existing or new medical test is unlikely to build up the body of evidence and therefore impact current practice.

Based on stakeholder discussion, it appears that iron staining of a bone marrow biopsy specimen is widely regarded as the “gold standard” for the diagnosis of (absolute) iron-deficient anemia, although this viewpoint is not universally accepted in the setting of CKD. Bone marrow iron may have limited clinical use due to the risks of infection or bleeding at the biopsy site. Despite these limitations, a bone marrow biopsy remains the most accurate measure that reflects stored iron, and thus should be used to define absolute iron deficiency. On the other hand, there is currently lack of a well-accepted reference standard for functional deficiency. Thus, we suggest that an expert panel be convened to standardize the definition for functional iron deficiency and determine which definition should be considered the preferred reference standard for diagnosing functional deficiency. The panel should also assess which intermediate outcomes (e.g., erythropoiesis-stimulating agent [ESA] or iron treatment dosages) or test characteristics (e.g., test availability/accessibility, cost) are appropriate to consider in determining the ideal definition for functional iron deficiency. In addition to representatives from all stakeholder categories, this panel should specifically include authoritative bodies and major professional organizations with relevant interests in iron deficiency, using a process similar to that used by the Centers for Disease Control and Prevention (CDC) Lipid Standardization Program (www.cdc.gov/labstandards/lsp.html).

FRN Topic 2 was Key Question 2 in the original CER. Although we did find studies comparing classical and newer tests for diagnosing absolute iron deficiency, they used classical laboratory biomarkers (alone or in combination with each other) as the reference standard for iron deficiency, essentially measuring the concordance between classical and newer biomarkers of iron status. Thus, we were unable to answer the question. We suggest that future research on this topic follow a prospective cohort design, as such studies would allow for multiple tests to be compared all together and potential biases could be minimized. In addition, depletion of bone marrow iron should be used as the reference standard for absolute iron deficiency, as iron staining of a bone marrow biopsy specimen is considered the most accurate measure that reflects stored iron. However, we expect that it will be difficult to recruit patients for such studies, because bone marrow aspiration is painful and poses risks to some patients.

FRN Topic 3 was also part of Key Question 2 in the original CER. Based on our post-hoc observation of this body of literature, we found that current studies often used a response to intravenous (IV) iron treatment as the reference standard for functional iron deficiency. However, there was no uniform regimen of IV iron in terms of dosage and iron formulation. There was also a wide range of durations of IV iron treatment across studies. These variations in the reference standards in the published studies resulted in incomparable study results, and limited the strength of body of evidence. Therefore we suggest that it is vital to establish a preferred reference standard for functional iron deficiency (also see FRN Topic 1), before future research on this topic go forward. Future research on this topic should use the same reference standard, in order to grow the body of evidence on this important research question in a manner amenable to systematic review and meta-analysis, to compare results across studies.

Similar to FRN Topic 2, we also suggest that future research on this topic also utilize a prospective cohort design, and the agreed upon (by the consensus expert panel) definition should be used as the reference standard for diagnosing functional iron deficiency. If the reference standard for functional iron deficiency is defined by a response to ESA or iron treatment, a sufficient washout period (at least 4 weeks) is needed to stop ESA and iron treatment before ascertainment of the baseline test measurements. Stopping treatment may not be feasible for some clinical settings. In this case, studies should recruit only CKD patients who did not receive ESA and iron treatment within 1 month before baseline test measurements.

Our CER did not directly address FRN Topics 4 and 5, so we suggest that as a first step, prior to conducting new research studies on these topics, an expert panel be convened to determine and prioritize the elements needed for design future research on these topics (such as which biomarkers and outcomes are appropriate and relevant to consider in determining an ideal marker to monitor response to therapy and repletion status, or monitoring iron overload). We noted that markers that can separate cell hemoglobinization from cell production would provide researchers a better chance of understanding the underlying mechanism, potentially enabling better targeted treatments and therefore better managed anemia. Markers that have specificity to responses related to ESA or iron delivery would be optimal.

In terms of the expert panel composition, to balance viewpoints the panel should specifically include clinical chemists and hematologists. Following identification of the most appropriate biomarkers by the expert panel and determination of a reference standard, prospective cohort studies with consecutive CKD patients are again, as in our previous suggestions, the ideal study design that should be conducted for future research on these topics. Moreover, future research on these topics should assess clinical or patient-centered outcomes.

## Discussion

The prioritization of topics for future research is a stakeholder-driven process. Our stakeholder panel represented a broad range of perspectives, from a well-informed patient advocate to clinical experts and policy makers. However, our stakeholder panel is unlikely to represent all perspectives because we did not use formal sampling methods to select our stakeholder members. The process of engagement though multiple teleconferences enabled us to get a well-rounded perspective; and we believe that the process of sharing the minutes of the discussions with all stakeholders enabled them to appreciate one another’s viewpoints. We were able to obtain input from all members of the stakeholder panel, and the final list showed a clear preference for the top five priorities.

There are several challenges for designing future research on the priority topics. The ideal study design and sampling populations would vary depending on the purpose of using a medical test (e.g., screening, diagnosis, prognosis, monitoring, etc.), in order to maximize the internal and external validity of a study. One of the challenges in the current FRN project is that an iron status test can be used for the purposes of screening, diagnosis, and/or monitoring for iron deficiency anemia in CKD patients. However, the same iron status tests can be used for the purposes of diagnosis and monitoring without considering the biases in interpretations of test results that are highly likely in these instances. Another challenge is that patients’ iron status can change spontaneously (due to changes in diet, or due to unrelated metabolic and inflammatory conditions) or due to the treatment received. Therefore, it is important to control for these confounding factors in future research studies, which will require large sample sizes to reach sufficient statistical power.

## Conclusions

Our CER and FRN stakeholder discussions pointed out the top future research gaps, and highlighted the great deal of confusion/uncertainty in using newer and/or classical laboratory biomarkers of iron status for the purposes of the diagnosis or monitoring of iron deficiency anemia in CKD patients. The chief factor causing this confusion and uncertainty is the lack of a well-accepted reference standard for iron deficiency anemia. The most effective first step would be to establish a common reference standard for iron deficiency anemia, considering two separate and distinct definitions: absolute versus functional iron deficiency. The ideal reference standard should be independent of the index tests and test-directed treatment to maximize the internal validity of study results.

## References

1 Anaemia Management in Chronic Kidney Disease - Rapid Update 2011. National Clinical Guideline Centre. 2011. www.ncbi.nlm.nih.gov/books/NBK65530/pdf/TOC.pdf.
2 Winkel P, Statland BE, Bokelund H. Factors contributing to intra-individual variation of serum constituents: 5. Short-term day-to-day and within-hour variation of serum constituents in healthy subjects. Clin Chem. Dec. 1974;20(12):1520-27. [pmid: 4430129].
3 Winkel P, Statland BE, Bokelund H. The effects of time of venipuncture on variation of serum constituents. Consideration of within-day and day-to-day changes in a group of healthy young men. Am J Clin Pathol. Oct. 1975;64(4):433-47. [pmid: 1239188].
4 Wish JB. Assessing iron status: beyond serum ferritin and transferrin saturation. Clin J Am Soc Nephrol. Sep. Suppl 1. 2006;1:S4-S8. [pmid: 17699374].
5 Chung M, Moorthy D, Hadar N, et al. Biomarkers for Assessing and Managing Iron Deficiency Anemia in Late-Stage Chronic Kidney Disease. Comparative Effectiveness Review No. 83. (Prepared by the Tufts Evidence-based Practice Center under Contract No. 290-2007-10055-I.) AHRQ Publication No. 12(13)-EHC140-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
6 Concannon T, Meissner P, Grunbaum J, et al. A New Taxonomy for Stakeholder Engagement in Patient-Centered Outcomes Research. Journal of General Internal Medicine. 2012:1-7. [pmid: 22086753].