# Acknowledgments

The authors gratefully acknowledge the stakeholders for their contributions to this project. Broad expertise and perspectives are sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant report. Therefore, in the end, study questions, design and/or methodologic approaches do not necessarily represent the views of individual stakeholder panel participants.

The authors would like to thank Ramon C. Iovin, Ph.D., who served as the medical editor for this report, and Lina Kong Win Chang, B.S., who provided administrative support.