# Discussion

## Challenges

The prioritization of topics for future research is a stakeholder-driven process. Our stakeholder panel represented a broad range of perspectives, from a well-informed patient advocate to clinical experts and policy makers. However, our stakeholder panel is unlikely to represent all perspectives because we did not use formal sampling methods to select our stakeholder members. The process of engagement though multiple teleconferences enabled us to get a well-rounded perspective, and we believe that the process of sharing the minutes of each discussion with all stakeholders enabled them to appreciate one another’s viewpoint. We were able to obtain input from all members of the stakeholder panel, and the final selection of prioritized future research topics showed a clear preference for the top 5 listed.

Medical tests are used to help treatment decisions for one or more purposes in the disease prevention and management process: determining predisposition (who could develop the disease), screening (who has asymptomatic disease), diagnosis (who has symptomatic disease), staging (how advanced is the disease), prognosis (how progressive will the disease be), stratification (who will be a responder), efficacy (is the drug effective), monitoring (is the disease controlled), to measuring recurrence (relapse of disease). The ideal study design and sampling populations to investigate a medical test would vary depending on the purpose of the test, in order to maximize the internal and external validity of a study. For example, to evaluate the test performance of a diagnostic test, it is ideal to recruit consecutive patients with or without anemia and who have not received any treatment. In contrast, to evaluate the test performance of a monitoring test, it is ideal to recruit consecutive patients who have been diagnosed with and are receiving treatment for anemia.

One of the challenges in the current FRN project is that an iron status test can be used for the purposes of diagnosis or monitoring for the iron deficiency anemia in CKD patients, but the published studies don’t often specify the purpose of the iron biomarkers evaluated. The same tests were being used for all three purposes without considering biases in interpretations of test results are highly likely to occur in this case. For example, treatment paradox occurs when treatment is started on the basis of the knowledge of the results of the index test, and the reference standard is applied after treatment has started. Another common bias arising in this situation is incorporation bias, which occurs when the index test is used to establish the final diagnosis. Thus, before future research on the top priority topics can be conducted, a truly independent reference standard of iron deficiency anemia must be established.

It should also be noted that patients’ iron status can change spontaneously (due to changes in diet or unrelated metabolic and inflammatory conditions) or based on the treatment received. Therefore, it is important to control for these confounding factors in future research, which will require large sample sizes to reach sufficient statistical power.

## Out-of-Scope Future Research Needs Topics

In addition to the 17 FRN topics eligible for prioritization, stakeholders identified 4 topics (Table 6) determined to be out-of-scope for the current FRN project. In general, topics were deemed out-of-scope if the state of the evidence was not rigorously assessed as part of the prior CER, such as studies of pediatric CKD patients, cost effectiveness and cost utility. Moreover, while these topics were areas of interest among stakeholders, some were not specific to anemia biomarkers (e.g., Topic #1), did not address test effectiveness (e.g., Topic #2), and could be viewed as major research fields unto themselves.

Table 6 Topics outside scope of Future Research Needs project

# | Topic
1 | What is the best method to translate the results of clinical tests to relevant management decisions?
2 | What is the availability of newer biomarkers in routine clinical practice?
3 | What is the impact of use of these tests on clinical practice?
4 | What is the best marker to identify erythropoietin hyporesponsive patients?