# Conclusions

Our CER and FRN stakeholder discussions identified the top future research gaps, and highlighted the great deal of confusion/uncertainty in using newer and/or classical laboratory biomarkers of iron status for the purposes of diagnosis or monitoring iron deficiency anemia in CKD patients. The chief factor causing this confusion and uncertainty is the lack of a well-accepted reference standard for iron deficiency anemia. The most effective first step would be to establish a common reference standard for iron deficiency anemia, considering two separate and distinct definitions: absolute and functional iron deficiency. The ideal reference standard should be independent of index tests and test-directed treatment to maximize the internal validity of study results.