# Background

## Context

Anemia is a common complication of chronic kidney disease (CKD), which develops early in the course of CKD and becomes increasingly severe as kidney function deteriorates.1 Iron deficiency anemia is a continuous process evolving in three stages. The first phase is the depletion of storage iron (stage I), where total body iron is decreased but hemoglobin (Hb) synthesis and red cell indices remain unaffected. Both these indices change when the supply of iron to bone marrow becomes problematic (iron deficient erythropoiesis, or stage II). In stage III the iron supply is insufficient to maintain a normal Hb concentration, and eventually iron deficiency anemia develops.

The management of anemia in CKD patients must strike an appropriate balance between stimulating generation of erythroblasts (erythropoiesis) and maintaining sufficient iron levels for optimum Hb production.2 It is important to assess iron stores and the availability of iron for erythropoiesis, as adequate iron status is integral to both iron and anemia management in CKD patients. The major cause of iron deficiency is blood loss, particularly for dialysis patients. Dialysis patients are in a state of continuous iron loss from gastrointestinal bleeding (very common), blood drawing, and/or, most importantly, with hemodialysis, the dialysis treatment itself. A CKD patient who receives treatment with erythropoietic-stimulating agents (ESAs) for the anemia often develops iron deficiency, because the iron requirements for achieving a response to ESA treatment usually cannot be met by mobilization of the patient’s iron stores alone. Therefore, supplemental iron therapy, either given orally or intravenously, is often needed among dialysis patients who receive recombinant human erythropoietin (EPO) or darbepoetin alfa treatment.1 Thus, iron management (iron status assessment and iron treatment) is an essential part of the treatment of anemia associated with CKD, as there are concerns regarding the adverse effects associated with both elevated doses of ESAs and supplemental (intravenous or oral) iron.

Classical iron status tests, of which ferritin and transferring saturation (TSAT) are the most widely used, reflect either the level of iron in tissue stores or the adequacy of iron for erythropoiesis. Though widely used, classical laboratory biomarkers of iron status are not without drawbacks when used in CKD patients: CKD is a pro-inflammatory state, and the biological variability of serum iron, transferrin saturation, and ferritin is known to be large in the context of underlying inflammation.3–5 Furthermore, results from a meta-analysis of 55 studies (published before 1990) showed that ferritin radioimmunoassay was the most powerful test (a mean area under the receiver operating characteristic curve of 0.95; 95% CI 0.94, 0.96), compared with mean cell volume determination, TSAT, and red cell volume distribution, for diagnosing adult patients with iron deficiency, but test performances varied between patients with and those without inflammatory (e.g., CKD patients) or liver disease.6 The accurate assessment of iron status is dependent on the validity and reliability of laboratory test results, and differences in test performance pose a dilemma regarding the most appropriate test to guide treatment decisions.

In an attempt to find a more accurate and reliable test, several novel biomarkers of iron status have been proposed:

- The Hb content of reticulocytes (CHr)/Reticulocyte hemoglobin equivalent (RetHe). CHr and RetHe measurements are functionally equivalent,7 but the two measurements are performed by different analyzers. CHr/RetHe, which examines both the precursors and mature red cells, provides an opportunity to detect and monitor acute and chronic changes in cellular hemoglobin status. CHr/RetHe measurement is a function of the amount of iron in the bone marrow that is available for incorporation into reticulocytes (immature red blood cells);8 decreased levels of CHr/RetHe indicate iron deficiency.
- The percentage of hypochromic erythrocytes (%HYPO). %HYPO is a measurement of Hb in red blood cell (RBC), which factors in the absolute Hb content as well as the size of the RBC.9 This can be used to measure functional iron deficiency. If iron supply is low in the face of ESA therapy, then there is lesser amount of Hb being incorporated into each RBC, and as a result, %HYPO levels are high.
- Erythrocyte zinc protoporphyrin (ZPP). ZPP is a measure of iron incorporation in heme. When iron levels are low, zinc is used instead of iron in the formation of heme, a protein component of Hb. As a result, ZPP levels increase, indicating iron deficiency.10
- Soluble transferrin receptor (sTfR). sTfR measures the availability of iron in the bone marrow. When the bone marrow is stimulated by ESAs, it results in increased expression of transferrin receptors on the surface of erythroblasts, the precursors of RBC. If iron supply is low, then levels of transferrin containing iron are low, and there is a mismatch between the numbers of transferrin receptors and the transferrin-iron complexes to bind with them. Some of the transferrin receptors which are not bound by iron-containing transferrin then get detached and can be detected in the blood. Increased concentration of sTfRs in the blood is an indicator of iron deficiency.
- Hepcidin. Hepcidin is a peptide produced by the liver that regulates both iron absorption in the intestine as well as release of iron from macrophages. Increased levels of hepcidin have indeed been associated with a decrease in available iron.11
- Superconducting Quantum Interference Devices (SQUIDs) are a non-invasive method for the detection and quantification of liver iron content.12 They operate by exploiting the paramagnetic properties of iron: magnetic resonance diminishes in the liver as iron concentration increases.

## Scope of Comparative Effectiveness Review

Although a number of international guidelines have examined the use of both classical and new serum iron biomarkers, their recommendations differ.1,2,13 In view of the considerable clinical uncertainty, the high biological variability associated with laboratory biomarkers, and the need for frequent assessment to guide treatment with ESAs, a systematic review of the relevant literature was deemed to be a priority. In order to address this knowledge gap, the Tufts Evidence-based Practice Center (EPC) conducted a Comparative Effectiveness Review (CER) to systematically evaluate the impact on patient-centered outcomes of using newer laboratory biomarkers^a^ as a replacement for or as an add-on to older laboratory biomarkers of iron status^b^ for assessing iron status and the management of iron deficiency in adult and pediatric CKD patients (nondialysis and dialysis).14 Although studies that assess the overall impact of these tests on the clinical management process would provide the most direct evidence for this CER, they are often challenging or unfeasible to conduct due to the high patient and resource requirements. Because it was expected that little such evidence would be found, the question of overall impact (Key Question 1; see below for full descriptions of all Key Questions) was broken out into three component Key Questions (Key Questions 2 to 4). Combining evidence that addresses these three component Key Questions could thus inform the conclusions for the review’s primary, overarching question (Key Question 1).

a Newer laboratory biomarkers: content of Hb in reticulocytes, percentage of hypochromic red blood cells, erythrocyte zinc protoporphyrin, soluble transferrin receptor, hepcidin, and superconducting quantum interference devices.

b Older laboratory biomarkers: bone marrow iron stores, serum iron, transferrin saturation, iron-binding capacity, and ferritin.

### Key Question 1 (Overarching Question)

What is the impact on patient centered outcomes of using the newer laboratory biomarkers as a replacement for or an add-on to the older laboratory biomarkers of iron status for assessing iron status and management of iron deficiency in stages 3–5 CKD patients (nondialysis and dialysis), and in patients with a kidney transplant?

### Key Question 2

What is the test performance of newer markers of iron status as a replacement for or an add-on to the older markers in stages 3–5 CKD patients nondialysis and dialysis, and in patients with a kidney transplant?

a. What reference standards are used for the diagnosis of iron status in studies evaluating test performance?
b. What are the adverse effects or harms associated with testing using newer and/or older markers of iron status?

### Key Question 3

In stages 3–5 nondialysis and dialysis CKD patients with iron deficiency, what is the impact of managing iron status based on newer laboratory biomarkers either alone or in addition to older laboratory biomarkers on intermediate outcomes (e.g., improvement in Hb levels, dose of erythropoiesis-stimulating agents, time in target Hb range), compared with managing iron status based on older laboratory biomarkers alone?

a. What are the adverse effects or harms associated with the treatments guided by tests of iron status?

### Key Question 4

What factors affect the test performance and clinical utility of newer markers of iron status, either alone or in addition to older laboratory biomarkers, in stages 3–5 (nondialysis and dialysis) CKD patients with iron deficiency? For example:

- Biological variation in diagnostic indices
- Use of different diagnostic reference standards
- Type of dialysis (i.e., peritoneal or hemodialysis)
- Patient subgroups (i.e., age, sex, comorbid conditions, erythropoiesis-stimulating agent resistance, protein energy malnutrition secondary to an inflammatory state, hemoglobinopathies [e.g., thalessemia and sickle cell anemia])
- Route of iron administration (i.e., oral or intravenous)
- Treatment regimen (i.e., repletion or continuous treatment)
- Interactions between treatments (i.e., patients treated with versus without ESA, patients treated with vs. without iron-replacement therapy)
- Other factors (based on additional information in the reviewed papers)

Each question had specific criteria for study inclusion based on the population, intervention, comparator, outcomes, and study design. Population criteria included studies in both adults and children with stage 3, 4, or 5 CKD; patients with CKD undergoing dialysis (hemodialysis [HD] or peritoneal dialysis [PD]); and patients with a kidney transplant. For interventions, eligible studies were those involving newer laboratory biomarkers to diagnose and manage iron deficiency either as a replacement for classical markers or in addition to classical biomarkers. For comparators, eligible studies were those involving older laboratory biomarkers to diagnose and manage iron deficiency. We were interested in both patient-centered outcomes (such as mortality and morbidity [e.g., cardiac or liver toxicity and infection], quality of life, and adverse events or harms) and intermediate outcomes (such as improvement in Hb levels, dose of erythropoiesis-stimulating agents, and time in target Hb range).

## Comparative Effectiveness Review Findings

A total of 30 articles met the study eligibility criteria, based on the populations, tests, and outcomes of interest, including one Polish- and one Japanese-language publication. Twenty seven articles reported data on the test performance of newer markers of iron status compared with classical markers (Key Question 2);7,15–40 two reported intermediate outcomes comparing iron management guided by newer laboratory markers with iron management guided by classical markers (Key Question 3);39,41 and three (in two articles) reported data on factors affecting test performance comparing newer with classical laboratory markers of iron status (Key Question 4).42,43 Most studies enrolled only adult CKD patients undergoing HD. The main findings of this CER are presented in Table 1.

Table 1 Strength of evidence addressing Key Questions

Key Questions | Strength of Evidence | Summary, Comments, and Conclusions
Key Question 2. What is the diagnostic test accuracy of newer markers of iron status as a replacement for or an add-on to classical laboratory markers? | Low/Insufficient (depending on the test comparisons, study populations, or test performance outcomes) | - Among adult HD CKD patients, there is a low level of evidence that:; ○ CHr has similar or better overall test accuracy compared with TSAT or ferritin to predict a response to IV iron treatment. Data from a few studies suggest that CHr (with cutoff values of <27 or <28 pg) has better sensitivity and specificity to predict iron deficiency than classical markers (TSAT <20 or ferritin <100 ng/mL).; ○ %HYPO has similar or better overall test accuracy compared with TSAT, and better overall test accuracy compared with ferritin to predict a response to IV iron treatment. Data suggest that %HYPO (with cutoff values of >6% or >10%) has a better sensitivity and specificity to predict iron deficiency (as defined by a response to IV iron treatment) than classical markers (TSAT <20% or ferritin <100 ng/mL).; ○ sTfR has a similar test performance compared with classical markers (TSAT or ferritin) to predict a response to IV iron treatment.; - There is insufficient evidence regarding:; ○ Test performance of newer markers of iron status as an add-on to older markers.; ○ Test performance comparing ZPP and hepcidin to predict a response to IV iron treatment in adult HD CKD patients.; ○ Test performance comparing newer with classical laboratory markers to predict a response to IV iron treatment, in adult PD CKD and ND CKD patients, and in pediatric CKD patients.
2a. What reference standards are used for the diagnosis of iron status in studies evaluating test accuracy? | Not rated (descriptive data) | - There is a lack of generally accepted reference standard tests for determining iron deficiency in the setting of CKD.2 This is reflected by the fact that current studies use two distinct methods to operationalize a reference standard for assessing test performance: 1) a response to IV iron treatment, often referred as “functional iron deficiency”; 2) classical laboratory biomarkers, alone or in combination with each other, often referred as “absolute iron deficiency.” However, across studies, there are large variations in the definitions of these reference standards.
2b. What are the adverse effects or harms associated with testing using newer and/or older markers of iron status? | Insufficient | - Only 7 of the 27 studies reported information:; ○ 3 studies reported no adverse events associated with iron therapy during the study periods.; ○ A total of 5 deaths reported. Studies did not attribute these deaths to either testing or any treatment.; ○ Most of the reported harms were attributed to iron therapy.
Key Question 3. What is the impact of managing iron status based on newer laboratory biomarkers either alone or in addition to older laboratory biomarkers on intermediate outcomes? | Low | - Two short-term RCTs (4 and 6 months) showed a reduction in the number of iron status tests and resulting intravenous iron treatments (a post-hoc intermediate outcome) administered to patients whose iron management. was guided by CHr compared with those guided by TSAT or ferritin.; - Both RCTs reported that Hct remained in the targeted ranges (an indication for the adequacy of anemia management) throughout the study period in all randomized arms, although the Hct target differed between the two trials.; - One trial showed that guiding iron management via CHr resulted in similar epoetin dosing compared with iron management guided by ferritin or TSAT. In contrast, the other trial found the doses of epoetin were significantly decreased (lower by 36%) in the group guided by TSAT, but did not change significantly in the group guided by CHr.; - No study compared iron management guided by classical markers with that of newer markers (%HYPO, sTfR, Ret-He, ZPP, or hepcidin).
3a. What are the adverse effects or harms associated with the treatments guided by tests of iron status? | Insufficient | - Only 1 RCT explicitly monitored the adverse events:; ○ There were a total of three deaths (2 patients in the CHr group; 1 patient in the TSAT group) due to bacterial pneumonia (at week 4 in the CHr group), sudden death by unknown cause (at week 16 in the CHr group), and liver tumor (at week 7 in the TSAT group).; ○ One patient in the TSAT group dropped out because of massive bleeding due to a femoral bone fracture and need for blood transfusion.; ○ There were no significant differences in the hospitalization or infection rates of the two iron management groups.
Key Question 4. What factors affect the test performance and clinical utility of newer markers of iron status? | Insufficient | - Only single study or indirect comparisons across studies provided data on the potential impacts of some factors on the test performance of newer or classical laboratory markers of iron status:; ○ One RCT found an interaction between iron and ESA treatment on test accuracy of CHr. A higher baseline CHr predicted greater likelihood of a response to anemia and iron treatment only in the IV iron (plus epoetin) treatment group, but not in the no IV iron (epoetin only) treatment group.; ○ One study showed that the test accuracy of RetHe was lower for assessing “functional iron deficiency” (TSAT<20%, ferritin 100–800 ng/mL, and Hb <11 g/dL) than for assessing “traditional parameters for iron deficiency” (serum iron < 40 μg/dL, TSAT<20%, ferritin <100 ng/mL, and Hb <11 g/dL) in HD CKD patients.; ○ Indirect comparisons across studies suggested potential impacts of route of iron administration and treatment regimen on the test accuracy of newer and classical laboratory markers of iron status.; - No study performed analyses by patient subgroups.; - No study examined the impacts of biological variation or type of dialysis in diagnostic indices on the test performance or clinical utility of laboratory markers of iron status.

Abbreviations: CHr = Hb content of reticulocytes; CKD = chronic kidney disease; ESA = erythropoiesis-stimulating agent; Hct = hematocrit; HB = hemoglobin; HD = hemodialysis; %HYPO = percentage of hypochromic erythrocytes; IV = intravenous; ND = nondialysis; PD = peritoneal dialysis; RCT = randomized controlled trial; RetHe = Reticulocyte hemoglobin equivalent; sTfR = soluble transferrin receptor; TSAT = transferrin saturation; ZPP = erythrocyte zinc protoporphyrin

Combining the evidence addressing Key Questions 2, 3, and 4, it was concluded that there is insufficient data to determine if most newer laboratory biomarkers of iron status are better than classical markers for predicting iron deficiency as defined by a response to iron challenge test. However, it may be that CHr and %HYPO have better predictive ability for a response to intravenous (IV) iron treatment than classical markers (TSAT <20% or ferritin <100 ng/mL) in HD CKD patients. In addition, results from two randomized controlled trials (RCTs) showed a reduction in the number of iron status tests and resulting IV iron treatments administered to patients whose iron management was guided by CHr compared with those guided by TSAT or ferritin. These results suggest that CHr may reduce potential harms from IV iron treatment by lowering the frequency of iron testing, although the evidence for the potential harms associated with testing or test-associated treatment is insufficient.

Nevertheless, the strength of evidence supporting these conclusions is low and there remains considerable clinical uncertainty regarding the use of newer markers in the assessment of iron status and management of iron deficiency in stages 3–5 CKD patients (both nondialysis and dialysis). In addition, factors that may affect the test performance and clinical utility of newer laboratory markers of iron status remain largely unexamined.

## Identification of Evidence Gaps

The current Future Research Needs (FRN) project was undertaken in order to find the most important research gaps in the literature with regards to laboratory tests for assessing iron status and management of iron deficiency in CKD patients, identified during the synthesis of the aforementioned CER. The objectives of this project are to identify potential research questions and to suggest study designs for addressing these questions. These objectives were achieved by cataloguing the evidence gaps relevant to iron deficiency laboratory tests, establishing a stakeholder panel, engaging stakeholders in research topic nomination and prioritization, and developing research protocols for the most highly ranked topics. Table 2 summarizes the evidence gaps identified in our review. (Note: The gaps are not listed in the order of the CER Key Questions.)

Table 2 Research gaps and suggestions for future research

Key Questions | Research Gaps
Key Question 1 (overarching question). What is the impact on patient centered outcomes of using the newer laboratory biomarkers as a replacement for or an add-on to the older laboratory biomarkers of iron status for assessing iron status and management of iron deficiency? | No studies were found that provided data directly addressing our overarching question regarding the impact of using newer laboratory biomarkers on patient-centered outcomes (e.g., mortality, morbidity, quality of life, and adverse effects). All gaps described in Key Questions 2, 3, and 4 are applicable to this overarching question.
Key Question 2. What is the diagnostic test accuracy of newer markers of iron status as a replacement for or an add-on to classical laboratory markers? 2a. What reference standards are used for the diagnosis of iron status in studies evaluating test accuracy? 2b. What are the adverse effects or harms associated with testing using newer and/or older markers of iron status? | Populations:; - Insufficient evidence in adult PD CKD and ND CKD patients.; - Whether test performance and clinical utility of newer or classical markers of iron status vary by different CKD populations is unknown.; Interventions and comparators:; - Insufficient evidence for the test performance of newer markers of iron status as an add-on to older markers.; Outcomes:; - There is a lack of a generally accepted reference standard test for determining iron deficiency in the setting of CKD.2; - A small percentage (26%) of the identified studies reported information on harms, and most studies did not attribute harms to either testing or treatment.; Study Design Issues:; - Many existing studies are at a high risk of bias due to lack of demographic details of study populations and blinding of the diagnosis or patient characteristics. These biases limit studies’ utility in informing clinical practice.; - Existing studies were underpowered leading to imprecise estimates.
Key Question 3. What is the impact of managing iron status based on newer laboratory biomarkers either alone or in addition to older laboratory biomarkers on intermediate outcomes? 3a. What are the adverse effects or harms associated with the treatments guided by tests of iron status? | Populations:; - Insufficient evidence in adult PD CKD and ND CKD patients.; Interventions and comparators:; - There are no uniform iron management algorithms or test-and-treat protocols across studies.; - There are lack of studies with longer followup durations; exsiting short-term RCTs had a followup duration less than 6 months.; - No study compared iron management guided by classical markers with that of newer markers (%HYPO, sTfR, RetHe, ZPP, or hepcidin), except for CHr.; Outcomes:; - The two RCTs showed different findings regarding the dose of epoetin required to maintain the Hct target as the primary outcome, possibly due to differences in the Hct targets (an indication for the adequacy of anemia management). Thus, the findings from the two RCTs could not be combined together. Important intermediate outcomes suggested by the experts include:; ○ Increase in Hb or hematocrit, or more consistent maintenance of Hb or hematocrit within the desired range; ○ Use of ESA for maintenance of Hb within the desired range (stable dose in contrast to escalating dose resulting in net decreased ESA dose in hyporesponsive patients or actual decreased ESA dose in relatively responsive patients); ○ Adverse effects or harms associated with different management strategies
Key Question 4. What factors affect the test performance and clinical utility of newer markers of iron status? | - Insufficient evidence to draw conclusions regarding factors that may affect the test performance or clinical utility of laboratory markers of iron status. Important factors suggested by the experts include:; ○ Biological variation in diagnostic indices; ○ Use of different diagnostic reference standards; ○ Type of dialysis (i.e., peritoneal or hemodialysis); ○ Patient subgroups (i.e., age, sex, comorbid conditions, erythropoiesis-stimulating agent resistance, protein energy malnutrition secondary to an inflammatory state, hemoglobinopathies [e.g., thalessemia and sickle cell anemia]); ○ Route of iron administration (i.e., oral or intravenous); ○ Treatment regimen (i.e., repletion or continuous treatment); ○ Interactions between treatments (i.e., patients treated with vs. without ESA, patients treated with vs. without iron-replacement therapy); - All gaps described in Key Questions 2 and 3 are also applicable here.

Abbreviations: CHr = Hb content of reticulocytes; CKD = chronic kidney disease; ESA = erythropoiesis-stimulating agent; Hct = hematocrit; HB = hemoglobin; %HYPO = percentage of hypochromic erythrocytes; ND = nondialysis; PD = peritoneal dialysis; RCT = randomized controlled trial; RetHe = Reticulocyte hemoglobin equivalent; sTfR = soluble transferrin receptor; ZPP = erythrocyte zinc protoporphyrin

One major evidence gap concerns the dearth of pediatric studies (only one study enrolled pediatric HD and PD CKD patients).22 This suggests that there is a need for further refinement of FRN for pediatric CKD patients (nondialysis and dialysis). Since this would require a specially-composed stakeholder group, it was determined to be beyond the scope of this project. Thus, the current FRN project is focused on adult CKD patients (nondialysis and dialysis).

## Analytic Framework

Figure 1 depicts the analytic framework used in structuring the CER as well as the FRN report. Broadly, it shows how the individual Key Questions are addressed within the context of the logical linkages between populations, interventions, comparators, and outcomes of interest.

Figure 1 Analytic framework

Abbreviations: CKD = chronic kidney disease; ESA = erythropoiesis-stimulating agents; Hb = hemoglobin level; KQ = Key Question

* The Comparative Effectiveness Review included both adult and pediatric CKD patients, but the current Future Research Needs project is focused on adult CKD patients (nondialysis and dialysis) only.

Figure 1 depicts the logical interconnection of Key Questions within the context of PICO (patient populations, interventions, comparators, and outcomes of interest). In general, the figure illustrates how alternative diagnostic tests and test-directed treatments may result in intermediate outcomes, such as changes in iron status, hemoglobin, and ESA dosing, and other clinical and patient centered outcomes, such as mortality, morbidity, and quality of life. Adverse events may occur at any point, related to testing or to test-directed treatment. Influencing factors may affect both test performance as well as have an impact on intermediate and patient-centered outcomes.