# Yield of Ongoing Studies

Search on ClinicalTrials.gov for ongoing research found eight studies with a search of: (iron deficiency OR response to iron) AND ((chronic kidney disease) OR dialysis) | Open Studies | Exclude Unknown | Adult, Senior

NCT ID | Title | Recruitment | Interventions | Enrollment
NCT01227616 | A Phase IV Trial of Ferumoxytol for the Episodic Treatment of Iron Deficiency Anemia in Patients With Chronic Kidney Disease | Not yet recruiting | Drug: Ferumoxytol | 300
NCT01102413 | Iron Isomaltoside 1000 (Monofer®) in Non-Dialysis Dependent Chronic Kidney Disease and With Renal-Related Anaemia | Recruiting | Drug: Monofer \| Drug: Iron Sulphate | 350
NCT00830037 | A Clinical Trial of Oral Versus IV Iron in Patients With Chronic Kidney Disease | Recruiting | Drug: IV Iron \| Drug: Ferrous Sulfate | 200
NCT01509690 | Impact of a Multidisciplinary Intensive Management Clinic on Outcomes in Multi-Ethnic Asian Incident Hemodialysis Patients | Recruiting | Other: Multidisciplinary, intensive and collaborative care | 150
NCT01587924 | 4 Week Switch Study in Hemodialysis-dependent Subjects With Anemia Associated With Chronic Kidney Disease | Recruiting | Drug: GSK1278863 \| Drug: rhEPO | 68
NCT01414075 | Study of FG-4592 to Correct Anemia in New Dialysis Patients | Recruiting | Drug: FG-4592 | 60
NCT01532349 | Vitamin D as a Modifier of Serum Hepcidin in Children With Chronic Kidney Disease | Not yet recruiting | Drug: Cholecalciferol | 28
NCT01138241 | Tenofovir Renal Toxicity and Glomerular Filtration Rate (GFR) Validation | Recruiting | Observational study | 700