# Future Research Needs Process

Abbreviations: CER = Comparative Effectiveness Review; EPC = Evidence-based Practice Center; FRN = Future Research Needs

Appendix A is a flow chart depicting the process for the future research needs project, from invitation of stakeholders and dissemination of background materials through topic nomination and ranking (before, during, and after two webinars), and development of research protocols for the final lists of future research needs topics.